# AUTHORS, CONTRIBUTORS, AND REVIEWERS

## CHEMICAL MANAGER/AUTHOR

- Bevin Blake, Ph.D.
  U.S. EPA, Center for Public Health and Environmental Assessment

## CONTRIBUTORS

- Avanti Shirke, MPH
  U.S. EPA, Center for Public Health and Environmental Assessment
- Geoffrey Peterson, Ph.D.
  U.S. EPA, Center for Public Health and Environmental Assessment
- Todd Zurlinden, Ph.D.
  U.S. EPA, Center for Public Health and Environmental Assessment
- Whitney Fies, Ph.D.
  ICF International Inc.
- Jeremy Frye, Ph.D.
  ICF International Inc.
- Jessica Wignall, Ph.D.
  ICF International Inc.

## PRODUCTION SUPPORT

- Dahnish Shams, MPH
  U.S. EPA, Center for Public Health and Environmental Assessment
- Jessica Soto-Hernandez
  U.S. EPA, Center for Public Health and Environmental Assessment

## PRIMARY INTERNAL REVIEWERS

- Laura Dishaw, Ph.D.
  U.S. EPA, Center for Public Health and Environmental Assessment
- Jay Zhao, Ph.D.
  U.S. EPA, Center for Public Health and Environmental Assessment

## EXTERNAL REVIEWERS

- Lisa Kamendulis, Ph.D.
  Indiana University
- Gloria B. Post, Ph.D., DABT
  New Jersey Department of Environmental Protection (retired)
- Angela Slitt, Ph.D.
  University of Rhode Island
- Anatoly Soshilov, Ph.D.
  California Environmental Protection Agency

## EXECUTIVE DIRECTION

- Wayne Cascio, MD - Center Director
  U.S. EPA, Center for Public Health and Environmental Assessment
- V. Kay Holt - Deputy Center Director
  U.S. EPA, Center for Public Health and Environmental Assessment
- Samantha Jones, Ph.D.- Associate Director for Risk Assessment
  U.S. EPA, Center for Public Health and Environmental Assessment
- Kristina Thayer, Ph.D.- Division Director, Chemical and Pollutant Assessment Division
  U.S. EPA, Center for Public Health and Environmental Assessment
- Andrew D. Kraft, Ph.D.- Associate Division Director, Chemical and Pollutant Assessment Division
  U.S. EPA, Center for Public Health and Environmental Assessment
- Janice S. Lee, Ph.D.- Branch Chief, Chemical and Pollutant Assessment Division
  U.S. EPA, Center for Public Health and Environmental Assessment