# DERIVATION OF REFERENCE VALUES

The hazard and dose response evidence base for 6:2 FTS is limited to studies with an oral route of exposure. No inhalation or dermal studies were identified. Further, there are no known studies evaluating potential cancer effects of 6:2 FTS, and studies relevant to potential cancer mechanism(s) are sparse and inconclusive. The purpose of this assessment is to inform human health hazard(s) associated with chronic duration/lifetime exposure to 6:2 FTS. Therefore, based on the current evidence base, only a chronic noncancer reference value is derived in this assessment for the oral route of exposure. This noncancer reference dose (RfD) is an estimate (with uncertainty spanning perhaps an order of magnitude) of a daily oral exposure to the human population (including susceptible subgroups and life stages) that is likely to be without an appreciable risk of adverse health effects during a lifetime.

## DERIVATION OF ORAL REFERENCE DOSE

Considering the available studies and focusing on medium or high confidence datasets as those most suitable for derivation of a toxicity value (U.S. EPA, 2022b), three medium confidence studies were advanced for potential dose-response analysis for 6:2 FTS. This included one epidemiological study that evaluated potential health effects of 6:2 FTS exposure in pregnant humans (Yang et al., 2016), one animal study reporting potential health effects of 6:2 FTS exposure in male mice after 28-days of oral gavage (Sheng et al., 2017), and one reproductive and developmental toxicity study in white-footed mice reporting on multiple endpoints following 112 days exposure of parental animals to 6:2 FTS (Bohannon et al., 2023).

The medium confidence, human study by Yang et al. (2016) was unable to support candidate value derivation as it only reported correlation coefficients and did not report regression coefficients with confidence intervals.

The 112-day study by Bohannon et al. (2023) was considered medium confidence for P0 immune, body weight, and organ weight endpoints; other evaluated endpoints were interpreted with low confidence and thus not considered for use in dose-response analysis (see HAWC (https://hawc.epa.gov/assessment/100500285/) for more details). In the study by Bohannon et al. (2023), P0 sample sizes were sufficient (N = 17-22 for females, N = 19-23 for males) and multiple doses were tested (0.2 – 25 mg/kg-d). There was a significant decrease in spleen plaque-forming cells (PFCs) in response to sheep red blood cells (SRBCs) in both 6:2 FTS-exposed P0 male (−59%) and P0 females (−57%) following exposure to 5 mg/kg-d with more severe effects observed in the 25 mg/kg-d group. Additionally, there was a significant increase in P0 male spleen weight (1, 5, and 25 mg/kg-d), though this effect is not considered as specific or sensitive for immunotoxicity as changes to spleen PFCs; thus, the spleen PFC endpoints were prioritized for dose-response analysis and the spleen weight change was not advanced.

The 28-day oral mouse study by Sheng et al. (2017) was considered medium confidence for all endpoints except histopathology, which was considered low confidence and thus not advanced for dose-response analysis (see HAWC (https://hawcprd.epa.gov/rob/study/101062948/) for more details). In the study by Sheng et al. (2017), the liver was selected by the study authors a priori as the focal tissue for examination due to the established link between legacy PFAS, such as PFOA and PFOS, and liver toxicity. This study suggests liver injury may be a target effect associated with repeat-dose oral exposure to 6:2 FTS. Therefore, the liver effects observed in male mice in the 28-day study (Sheng et al., 2017) were considered for the derivation of a RfD. Relative liver weight was advanced over the other medium confidence endpoints due to the biologically significant magnitude of the effect (+22% increase relative to controls) and the consistency of increased liver weight across other well-studied PFAS. The remaining medium confidence liver effects were not selected for the derivation of a RfD as increased AST or albumin levels are not as specific as the other endpoints to liver damage (i.e., increased AST can indicate pancreatitis and increased albumin can indicate dehydration). While the histopathological findings reported by Sheng et al. (2017) were of low confidence and not considered in the derivation of an RfD, it is noted these findings provide support for the use of increased liver weight as the critical endpoint.

The datasets advanced for dose-response analysis are summarized in Table 6.

Table 6 Data for Liver and Immune Effects in Adult Mice from Toxicity Studies of 6:2 FTS Considered for BMD Modeling

Endpoint | Dose, mg/kg-d^a^
(Sheng et al., 2017)
| 0 | | | 5
Relative liver weight in adult males (% of BW)^b^ | 4.01 ± 0.05 | | | 4.91 ± 0.24^*^; (+22%)
Animals (n) | 10 | | | 10
(Bohannon et al., 2023)
| 0 | 0.2 | 1.0 | 5.0 | 25.0
SRBC-induced formation of plaque-forming cells in spleen in adult males (PFC/million cells)^b^ | 1450 ± 197 | 1040 ± 123; (−28%) | 1270 ± 183; (−12%) | 597 ±76.1^*^; (−59%) | 192 ± 20.8^*^; (−87%)
SRBC-induced formation of plaque-forming cells in spleen in adult females (PFC/million cells)^b^ | 908 ± 123 | 1070 ± 197; (+18%) | 1120 ± 287; (+23%) | 392 ± 48.5^*^; (−57%) | 258 ± 56.5^*^; (−72%)
Animals (n) | 21-22 | 21 | 20-21 | 19-21 | 18-19

a Dosimetry: Oral mouse exposures are expressed in mg/kg-day as reported by the study authors.

b Values expressed as mean ± SE. Parentheses show % change relative to control = ([treatment mean − control mean] ÷ control mean) × 100.

* Statistically (p ≤ 0.05) and biologically (>10%) significant change from control.

The 6:2 FTS-induced liver effects, specifically increased relative liver weight, observed in male mice in the study by Sheng et al. (2017) could not be evaluated with benchmark dose (BMD) modeling as the study only included one experimental dose, 5 mg/kg-day (see Table 6). Instead, a LOAEL approach was used to estimate a POD for this endpoint. The 6:2 FTS-induced immune effects observed in adult P0 male and female mice in the 112-day study by Bohannon et al. (2023) were evaluated for amenability to benchmark dose (BMD) modeling. Consistent with the EPA’s Benchmark Dose Technical Guidance (U.S. EPA, 2012), the BMDs and 95% lower confidence limit on BMDs (BMDLs) for decreased spleen PFCs were estimated using a benchmark response (BMR) representative of a minimally significant level of change for continuous endpoints (in this case a BMR of 1SD of the control mean was selected as the recommended standard reporting level in the absence of information on an endpoint specific biologically significant level of change^2^). The results of the BMD modeling of selected endpoints are provided in Table 7; the full BMD methods are provided in Appendix B.

2 The evidence to inform an appropriate BMR is limited for decreased SRBC-induced spleen PFCs. The PFC assay is a reliable endpoint of immunotoxicity (IPCS, 2012) with an estimated predictive concordance with immunotoxicity of 73% (Luster et al., 1993). However, the biological significance and human health relevance of this effect is not well characterized. Due to this uncertainty, it is recommended for continuous data in the Benchmark Dose Technical Guidance Document (U.S. EPA, 2012), that a change in the mean response equal to 1 SD of the control mean was used as the BMR to facilitate a consistent basis of comparison across assessments for this endpoint in the absence of information regarding the level of change considered to be biologically significant.

Table 7 Candidate PODs for Derivation of the Chronic RfD for 6:2 FTS

Endpoint | POD type | POD (mg/kg-d) | POD_HED_^a^ mg/kg-d | Reference
Decreased SRBC-induced spleen PFCs in adult males | BMDL_1SD_ | 1.51 | 0.200 | Bohannon et al. (2023)
Decreased SRBC-induced spleen PFCs in adult females | BMDL_1SD_ | 2.24 | 0.290 | Bohannon et al. (2023)
Increased relative liver weight in adult males | LOAEL | 5 | 0.739 | Sheng et al. (2017)

a HED was calculated using species specific application of a dosimetric adjustment factor (DAF) as recommended by (U.S. EPA, 2011). The DAF is calculated as follows: DAF = (BW_a_^1/4^ ÷ BW_h_^1/4^), where BW_a_ = animal body weight, and BW_h_ = human body weight. Mouse body weight was derived from the study using the mean terminal body weight of treated mice of 0.021558 kg for adult males (Bohannon et al., 2023), 0.0199780 kg for adult females (Bohannon et al., 2023), or 0.03334 kg (Sheng et al., 2017) (which did not differ significantly from the control group) and a reference value of 70 kg for human body weight was used based on (U.S. EPA, 1988) to calculate the DAFs. Using a reference value of 80 kg for human body weight would result in a near-identical HEDs.

In Recommended Use of Body Weight^3/4^ as the Default Method in Derivation of the Oral Reference Dose (U.S. EPA, 2011), the EPA outlines a hierarchy of approaches to derive human equivalent oral exposures from data from laboratory animal species, with the preferred approach being physiologically based toxicokinetic modeling. Without a complete physiologically-based toxicokinetic model, other approaches might include using available chemical-specific information (e.g., clearance or plasma half-life values). In the absence of chemical-specific models or data to inform the derivation of human equivalent oral exposures, the EPA recommends that doses be scaled allometrically using body weight (BW)^3/4^ as a default method to extrapolate toxicologically equivalent doses or orally administered agents from laboratory animals to humans for the purpose of deriving an RfD, under certain exposure conditions. More specifically, the use of BW^3/4^ scaling for deriving an RfD is recommended when the observed effects are associated with the parent compound or a stable metabolite, but not for portal-of-entry effects. For 6:2 FTS, there are no data available to inform cross-species kinetics between mice and humans, as such, human equivalent doses (POD_HED_) based on allometric scaling are provided in Table 7.

As shown in Table 7, the POD_HED_ values for liver and immune effects in adult mice following 28-day and 112-day exposures, respectively, ranged from 0.200-0.739 mg/kg-d. Decreased SRBC-induced spleen PFCs in adult male mice provided the lowest POD_HED_ at 0.200 mg/kg-d. Decreased induced PFCs in the spleen is indicative of immune suppression (IPCS, 2012), specifically T-cell dependent IgM responses, and is consistent with immunotoxic effects identified in prior animal studies and human health assessments evaluating other PFAS ((Woodlief et al., 2021; Dewitt et al., 2019; Antoniou et al., 2022); EPA IRIS Assessment for PFHxA (U.S. EPA, 2023), PFOS (U.S. EPA, 2024b), and PFOA (U.S. EPA, 2024c), ATSDR Toxicological Profile for Perfluoroalkyls (ATSDR, 2021)). Similarly, the increased liver weight effect observed in the study by Sheng et al. (2017) is consistent with many other studies of PFAS hepatotoxicity and is part of a well-documented constellation of liver effects frequently observed following exposure to well-studied PFAS (EPA IRIS Assessment for PFBA (U.S. EPA, 2022a), and PFHxA (U.S. EPA, 2023), EPA Office of Water Human Health Toxicity Values for HFPO-DA (U.S. EPA, 2021c), PFOS (U.S. EPA, 2024b), and PFOA (U.S. EPA, 2024c); ATSDR Toxicological Profile for Perfluoroalkyls (ATSDR, 2021)).

### Selection of the Chronic Reference Dose

Under EPA’s A Review of the Reference Dose and Reference Concentration Processes (U.S. EPA, 2002) and Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (U.S. EPA, 1994), five possible areas of uncertainty and variability were considered in deriving the chronic RfD for 6:2 FTS. Application of uncertainty factors (UF) across the critical effect PODs revealed greater composite uncertainty associated with the increased liver weight effect and POD; a composite UF of 30,000 was identified for increased liver weight in adult male mice whereas for increased spleen PFCs in adult males and females, a composite UF of 1000 was applied (see Tables 8 and 9). The distinction between the effects is that for the increased liver weight POD_HED_, a LOAEL-to-NOAEL (UF_L_) of 10 was applied as the study only included one experimental dose and a NOAEL could not be identified and a subchronic-to-chronic uncertainty factor (UF_S_) of 10 was applied as the study was only 28 days in duration. For the decreased spleen PFCs in adult males and females POD_HED_, a UF_L_ of 1 was applied due to the study using multiple doses and the endpoint was amenable to BMD modeling and a UF_S_ of 3 was applied as the study was 112 days in duration.

Table 8 Candidate Chronic Values for 6:2 FTS

Endpoint | POD_HED_ mg/kg-d | UF_A_ | UF_D_ | UF_H_ | UF_L_ | UF_S_ | UF_C_ | Candidate Value (mg/kg-d)
Decreased SRBC-induced spleen PFCs in adult male mice.; Bohannon et al. (2023) | 0.200 | 3 | 10 | 10 | 1 | 3 | 1000 | 0.0002
Decreased SRBC-induced spleen PFCs in adult female mice.; Bohannon et al. (2023) | 0.290 | 3 | 10 | 10 | 1 | 3 | 1000 | 0.00029
Increased relative liver weight in adult male mice.; Sheng et al. (2017) | 0.739 | 3 | 10 | 10 | 10 | 10 | 30,000 | 0.00002^a^

UFC = Composite UF = UFA × UFD × UFH × UFL × UFS.

a The Agency notes that when there’s maximum uncertainty in four areas this may indicate that the database is insufficient to derive a reference value and recommends avoiding derivation of a reference value that involves application of the full 10-fold UF in four or more areas of extrapolation (US EPA, 2002). Thus, this 30,000-fold UF and the resulting candidate value of 0.00002 will not be further considered in this assessment.

Table 9 Uncertainty Factors for the Candidate Chronic Values for 6:2 FTS

UF | Value | Justification
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic and toxicodynamic differences between animals and humans following oral 6:2 FTS exposure. Cross-species dosimetric adjustment (HED calculation) was performed using default allometric BW^3/4^ scaling between mice and humans. This scaling is applied to account for some aspects of the cross-species toxicokinetic processes. A factor of 3 is applied to account for residual toxicokinetic uncertainty and potential toxicodynamic differences across species.
UF_D_ | 10 | A UF_D_ of 10 is applied to account for deficiencies and uncertainties in the database. The database for oral exposure to 6:2 FTS is limited to one human epidemiological study of medium confidence and two repeat-dose oral mouse studies of medium confidence. Other available studies were of low confidence or uninformative or did not report on outcomes relevant to 6:2 FTS exposure, and thus the potential for sensitive effects (e.g., reproductive, or developmental effects) has not been adequately examined for 6-2 FTS.
UF_H_ | 10 | A UF_H_ of 10 is applied to account for interindividual variability in the susceptibility of the human population because of both intrinsic and extrinsic factors that can influence the response to dose, in the absence of chemical-specific information to assess toxicokinetic and toxicodynamic variability of 6:2 FTS in humans.
UF_L_ | 1 | A UF_L_ of 1 is applied to the PODs from Bohannon et al. (2023) because the PODs are BMDLs.
UF_L_ | 10 | A UF_L_ of 10 is applied to the POD from Sheng et al. (2017) because the POD is a LOAEL.
UF_S_ | 3 | A UF_S_ of 3 is applied to the PODs from Bohannon et al. (2023) to account for uncertainty in how a longer exposure duration more relevant to lifetime exposure might impact the incidence or severity of immune effects observed after subchronic exposure. The PODs were derived from a 112-d study, a duration longer than the typical full lifespan of T cells in mice, so a UF_S_ of 10 was considered unnecessary and a 3-fold UF was applied.
UF_S_ | 10 | A UF_S_ of 10 is applied to the POD from Sheng et al. (2017) given the large uncertainty in the potential for increases in the incidence or severity of liver injury when extrapolating effects from a 28-d study to lifetime exposure.

BMDL = benchmark dose lower confidence limit; HED = human equivalent dose; POD = point of departure; RfD = reference dose; UF = uncertainty factor; UF_A_ = interspecies uncertainty factor; UF_D_ = database uncertainty factor; UF_H_ = intraspecies uncertainty factor; UF_L_ = LOAEL-to-NOAEL uncertainty factor; UF_S_ = subchronic-to-chronic duration uncertainty factor.

From among the candidate toxicity values, the value for decreased SRBC-induced spleen PFCs in adult male mice (Bohannon et al., 2023) was selected to represent the chronic RfD. Both the immune and liver effects were the effects best supported by the available evidence base, and both are consistent with findings for other well-studied PFAS. Although the candidate value for liver effects based on Sheng et al. (2017) was lower, this was driven by the high level of uncertainty reflected in the application of uncertainty factors. As noted in the footnote for Table 8, the Agency notes that when there is maximum uncertainty in four areas this may indicate that the database is insufficient to derive a reference value and recommends avoiding derivation of a reference value that involves application of the full 10-fold UF in four or more areas of extrapolation (US EPA, 2002). Thus, the 30,000-fold UF and the resulting candidate value of 0.00002 related to the liver effects reported by Sheng et al. (2017) are not considered appropriate for RfD selection in this assessment. The selected Bohannon et al.(2023) value was associated with far less uncertainty and the POD underlying the immune effect was actually lower than the POD underlying the liver effects; thus, if uncertainty in the liver effects value were reduced, the candidate values would be similar. The RfD is based on the immune finding in adult males as it was marginally more sensitive, and thus likely to be protective, of the effect in adult females.

The chronic RfD was derived by applying a composite uncertainty factor (UF_C_) of 1000 (reflecting an interspecies uncertainty factor [UF_A_] of 3, a database uncertainty factor [UF_D_] of 10, an intraspecies uncertainty factor [UF_H_] of 10, a LOAEL-to-NOAEL [UF_L_] uncertainty factor of 1, and a subchronic-to-chronic uncertainty factor [UF_S_] of 3) to the POD_HED_ of 0.200 mg/kg-day (Table 10). Confidence in the chronic RfD for 6:2 FTS is Low, as described in Table 10. The low confidence in the chronic RfD, resulting primarily from the limited available hazard and dose-response relevant evidence in the database.

Chronic RfD = POD_HED_ ÷ UF_C_ = 0.200 mg / kg-day ÷ 1000 = 0.0002 or 2 × 10^− 4^ mg / kg-day

Table 10 Confidence Descriptors for the Chronic RfD for 6:2 FTS

Confidence categories | Designation | Discussion
Confidence in study | M-L | Confidence in the principal study (Bohannon et al. (2023)) was medium-low. Although the study was rated medium confidence for the endpoints considered in RfD derivation (information available in HAWC (https://hawc.epa.gov/summary/visual/assessment/100500285/62-FTS-study-evaluation-heatmap/)), confidence is reduced due to use of a non-standard rodent model with unclear relative sensitivity compared to typically used rodent strains and low confidence in most other endpoints from this study.
Confidence in database | L | Confidence in the database for 6:2 FTS is low. The relevant human health assessment database consists of one medium confidence human epidemiologic study, two medium confidence repeat-exposure oral gavage studies in mice (28-d and 112-d), and non-peer reviewed oral exposure studies of low and uninformative confidence on short-term, reproductive, developmental, kidney, and subchronic toxicity of 6:2 FTS in rodents.
Confidence in the quantification of the POD_HED_ | M | Confidence in the quantification of the POD and RfD is medium. The POD was based on BMD modeling within the range of the observed data. Dosimetric adjustment of the POD was based on the default BW^3/4^ scaling due to lack of chemical specific toxicokinetic data (e.g., clearance, half-life). Although a biologically based BMR for the induced effects on mouse PFCs could not be determined, the observed magnitude of change in this endpoint at 1SD may be associated with an increased susceptibility to infection, based on prior studies of immunosuppressants.
Confidence in the chronic RfD | L | Overall low confidence is driven by low confidence in the database for 6:2 FTS.

BMD = benchmark dose; HED = human equivalent dose; POD = point of departure; RfD = reference dose; M = medium confidence; L = low confidence.

## DERIVATION OF INHALATION REFERENCE CONCENTRATIONS

No studies have been identified that examine noncancer effects of 6:2 FTS via the inhalation exposure route.

## SUMMARY OF NONCANCER REFERENCE VALUES

Noncancer reference values are summarized in Table 11.

Table 11 Summary of Noncancer Reference Values for 6:2 FTS

Toxicity type (units) | Species/sex | Critical effect | Reference value mg/kg-d and Confidence | POD type | POD_HED_ mg/kg-d | UF_C_ | Principal study
Chronic RfD (mg/kg-d) | Mouse/M | Decreased SRBC-induced spleen PFCs | 0.0002; Low Confidence | BMDL_1SD_ | 0.200 | 1000 | Bohannon et al. (2023)
Chronic RfC (mg/m^3^) | NDr

RfD = Reference Dose, RfC = Reference Concentration, LOAEL = Lowest Observable Adverse Effect Level, POD = Point of Departure, HED = Human Equivalent Dose, NDr = Not Derived, UF_C_ = Composite Uncertainty Factor.

## CARCINOGENICITY ASSESSMENT

No studies have been identified that examine potential carcinogenicity of 6:2 FTS via any route of exposure. Therefore, carcinogenicity could not be evaluated, and no cancer toxicity values are derived.