# RESULTS

## Literature Search and Screening Results

The database searches yielded 140 references for 6:2 FTS and its related salts. After exclusion of duplicates and non-PECO relevant references, one human, nine animal, and 95 supplemental studies from the 140 initial references with information relevant to understanding the potential health effects of 6:2 FTS were identified (Figure 1). Of the 30 CBI or 3M documents submitted to EPA, only two were not represented in the PFAS 150 SEM literature results. The two documents not represented in the PFAS 150 SEM described acute studies that were ultimately not included. In addition, an acute study from ECHA was not included. Longer duration studies were available and thus these three acute studies were not considered impactful to deriving chronic toxicity values. A total of 33 studies most relevant for deriving chronic toxicity values were identified, including one human, eight animal, and 26 supplemental studies reporting on genotoxicity, mechanistic toxicity, or absorption/distribution/metabolism/excretion (ADME) which are summarized below.

Figure 1 6:2 Fluorotelomer sulfonic acid literature search flow diagram

References meeting PECO were also tagged as containing supplemental information when relevant (e.g., study reported on animal health effects and mechanistic evidence). Supplemental studies were tagged to multiple categories when relevant. *Three acute exposure studies met PECO criteria but were not considered impactful to deriving chronic toxicity values and were not included. These studies included two CBI documents submitted to EPA and one ECHA report (ECHA, 2017).

## Human Studies

One medium confidence epidemiology study was identified in the literature search (Yang et al., 2016) (see Figure 2, see Table 2). This study of 157 pregnant persons and newborns in China measured 6:2 FTS and thyroid hormone levels in maternal serum samples (collected 1–2 days before delivery; 82% of samples >LOD) and cord serum (collected immediately after delivery; 90% of samples >LOD). Concentrations of 6:2 FTS were similar in both samples (maternal serum median [range]: 41 [<LOD-203] pg/mL; cord serum median [range]: 25 [<LOD-252] pg/mL), though it should be noted concentrations of 6:2 FTS were three orders of magnitude lower than PFOA (maternal serum median [range]: 1.64 [0.73-8.11] ng/mL, cord serum median [range]: 1.15 [0.40-5.06] ng/mL) and PFOS (maternal serum median [range]: 4.41 [0.73-19.96] ng/mL, cord serum medium [range]: 1.18 [0.24-6.93] ng/mL) (Table 2). Maternal serum 6:2 FTS levels were statistically significantly positively correlated with maternal serum levels of free triiodothyronine (FT3, r = 0.160), triiodothyronine (T3, r = 0.205), free thyroxine (FT4, r = 0.164), and thyroxine (T4, r = 0.172) in analyses adjusted for maternal age, maternal prepregnancy BMI, maternal monthly income, and neonatal type of delivery; no association was reported with TSH. For fetal thyroid hormones measured in cord serum (a surrogate measure for fetal levels), no statistically significant associations with exposure to 6:2 FTS were reported with exposure measured in either maternal or cord serum in adjusted models, though there was a weak inverse association detected between fetal cord 6:2 FTS and fetal free T3 (r = −0.106), fetal free T4 (r = −0.180), and fetal T3 (−0.042). Sensitivity was considered limited in this study due to very narrow exposure contrasts and potential for non-differential outcome misclassification (resulting from lack of consideration of diurnal variation of hormone levels), so the lack of association should not necessarily be interpreted as evidence of no effect. Overall, there is limited evidence of an association between 6:2 FTS exposure and thyroid hormones in pregnant persons or neonates, with weak correlations between 6:2 FTS and thyroid hormones. There is potential for confounding by other correlated PFAS, but this is expected to be minimal given the weak correlations with other PFAS (e.g., the highest correlation with another measured PFAS was PFOA with r = 0.24) and the fact that the other PFAS were mostly associated with hormones in the inverse direction. This outcome was not selected as a critical effect due to the weak association between maternal 6:2 FTS and thyroid hormone levels.

Figure 2 Summary of study evaluation for epidemiological study of 6:2 FTS and all health outcomes

Interactive figure and additional study details available on HAWC. https://hawc.epa.gov/summary/visual/assessment/100500285/62-FTS-study-evaluation-heatmap-human-study/

Table 2 Associations Between 6:2 FTS Exposure and Health Effects in Epidemiological Studies

Reference, confidence | Location, yrs | Design | Population (N) | Exposure matrix and levels (pg/mL) | Outcome | Comparison | Select results^a^
General Population
Yang et al. (2016); Medium (https://hawcprd.epa.gov/rob/study/101156700/) | China, 2013 | Cross-sectional | Pregnant women (N = 157) | Maternal serum:; Mean ± SD = 4; 8.38 ± 40.94; Median = 41.44; Geometric mean = 26.04; Range = <LOD −203 | Maternal serum thyroid hormone levels (µIU/mL) | Spearman correlation between maternal serum 6:2 FTS levels and maternal serum thyroid hormones | FT3: 0.160 (p < 0.05); FT4: 0.164 (p < 0.05); T3: 0.205 (p < 0.05); T4: 0.172 (p < 0.05); TSH: −0.013 (p > 0.05)
Yang et al. (2016); Medium (https://hawcprd.epa.gov/rob/study/101156700/) | China, 2013 | Cross-sectional | Pregnant women (N = 157) | Cord serum:; Mean ± SD = 3; 3.54 ± 38.52; Median = 24.68; Geometric mean = 19.98; Range = <LOD −252.12 | Maternal serum thyroid hormone levels (µIU/mL) | Spearman correlation between cord serum 6:2 FTS levels and maternal serum thyroid hormones | FT3: −0.122 (p > 0.05); FT4: −0.001 (p > 0.05); T3: −0.076 (p > 0.05); T4: −0.056 (p > 0.05); TSH: 0.127 (p > 0.05)

a Results reported as Spearman correlation coefficients from models adjusting for maternal age, maternal pre-pregnancy BMI, maternal monthly income, and type of delivery.

Free T3 = free triiodothyronine, FT4 = free thyroxine, T3 = triiodothyronine, T4 = thyroxine.

## Animal Studies

A total of eight animal studies were identified in the literature search and were conducted using rats (ECHA, 2018a, b, c, 2020d) or mice (Sheng et al., 2017; Narizzano et al., 2021; ECHA, 1995; Bohannon et al., 2023). For study details, see HAWC (https://hawc.epa.gov/study/assessment/100500285/) and for a list of reported endpoints see the evidence profile table (https://hawc.epa.gov/summary/assessment/100500285/tables/6-2-FTS-Evidence-Profile-Table/) in HAWC. Five of these studies were non-peer reviewed reports with minimally detailed experimental methods and qualitative or semi-quantitative results generated by the European Chemicals Agency (ECHA) and thus had study evaluation ratings of low confidence or uninformative (Figure 3). Another of these studies was considered uninformative due to qualitative reporting of toxicological endpoints and low accuracy of 6:2 FTS concentrations in the dosing solutions in addition to contamination of dosing solutions with other PFAS (e.g., 4:2 FTS and 8:2 FTS, among others) (Narizzano et al., 2021).

Figure 3 Study evaluation results for experimental animal studies of 6:2 FTS meeting PECO criteria

Striped cells correspond to studies reporting multiple endpoints with different confidence judgements. Interactive figure and additional study details available on HAWC. https://hawc.epa.gov/summary/visual/assessment/100500285/62-FTS-study-evaluation-heatmap/

Thus, only results from two animal studies were interpreted as having endpoints considered greater than low confidence (Sheng et al., 2017; Bohannon et al., 2023).

Bohannon et al. (2023), exposed male and female parental (P0) white-footed mice (Peromyscus leucopus) to 0, 0.2, 1, 5, or 25 mg/kg-d 6:2 FTS via oral gavage for a total of 16 weeks beginning 4 weeks premating. Immune, body weight, and organ weight effects reported in this study were considered medium confidence while P0 serum hormone measures and P0 reproductive and F1 developmental effects were considered low confidence due to non-preferred reporting of outcomes and high offspring mortality rates in the control group (~20%). Histopathology findings for P0 adults (liver, spleen, and thymus) were considered uninformative due to deficiencies in methods reporting and qualitative reporting of results (see HAWC (https://hawc.epa.gov/study/101400025/) for further details).

Focusing on the medium confidence endpoints, no effects were observed on P0 animal body weights or P0 animal organ weights (adrenals, brain, heart, kidneys, relative liver weight, ovaries, spleen, thymus, or uterus) with the exception of P0 male spleen weights, which were significantly increased (+35% relative to controls at 5 mg/kg-d) (Bohannon et al., 2023). P0 animals also had significantly decreased plaque-forming cells (PFCs) in the spleen in response to sheep red blood cells (SRBCs) relative to controls (−57% for females and −59% for males) (see Figure 4). This finding, which is a more sensitive and specific measure of immunotoxicity than organ weight, is suggestive of immune suppression, specifically the humoral immune IgM antibody-forming cell response (Luster et al., 1988).

Certain effects commonly associated with toxicity of other PFAS (e.g., liver, developmental) were notably absent in the study by Bohannon et al. (2023). However, the white-footed mouse is not a commonly used rodent model in studies conducted to inform potential human health toxicity. Among commonly used laboratory rodent strains, there are known species and strain differences in sensitivity to PFAS. Toxicological studies comparing the sensitivity of the white-footed mouse to more commonly used rodent models to inform potential differences in sensitivity of white-footed mice towards 6:2 FTS, PFAS, or certain effects more generally were not identified. This is a research gap.

Figure 4 Immune effects following oral exposure to 6:2 FTS

Interactive figure available on HAWC. https://hawc.epa.gov/summary/data-pivot/assessment/100500285/Data-pivot-Spleen-endpoints/

The 28-day daily oral gavage study by Sheng et al. (2017) in CD-1 mice exposed adult males to 0 or 5 mg/kg-day 6:2 FTS and reported body weight, liver weight (relative and absolute), liver concentrations of triglycerides (TG) and total cholesterol (T-CHO), liver histopathology, and serum levels of triglycerides, total cholesterol, alanine aminotransferase (ALT), aspartate transaminase (AST), high density lipoprotein (HDL), low density lipoprotein (LDL), alkaline phosphatase (ALP), albumin (ALB), and total bile acids (TBA). All endpoints were rated as medium confidence except for the histopathological findings, which were rated as low confidence due to the qualitative nature of reporting for this endpoint (see HAWC page for further details: https://hawc.epa.gov/rob/study/101164335/). 6:2 FTS exposure did not affect body weight. Following exposure to 5 mg/kg-day 6:2 FTS, there was a significant increase in absolute (18.8%) and relative (22.4%) liver weights relative to controls (see Figure 5). Serum levels of AST and ALB were also significantly increased following exposure by 31% and 10% relative to controls, respectively, but no significant changes in other serum or liver clinical chemistry measures were reported. Histopathological observations consistent with liver injury, including necrosis and hepatocellular hypertrophy (the latter confirmed by observed decreases in cell counts observed per area examined) were qualitatively reported in the livers of mice exposed to 6:2 FTS, but these results are interpreted with low confidence. Other mechanistic evidence from this study suggests 6:2 FTS exposure induces inflammation, including in the liver, and disrupts liver gene expression (see Other Evidence below).

Figure 5 Liver effects following oral exposure to 6:2 FTS

Interactive figure available on HAWC. https://hawc.epa.gov/summary/data-pivot/assessment/100500285/Data-pivot-Liver-endpoints/

The five non-peer reviewed ECHA reports that reported results qualitatively or semi-quantitatively included short-term, developmental, reproductive, and subchronic oral exposure studies all were rated as low confidence or uninformative (see Figure 3). The earliest report was generated in 1995 and describes a study conducted in male CD-1 mice that were exposed to different doses of 6:2 FTS in their diet (0, 0.57, 5.68, 56.8, and 567.8 mg/kg-day) and exhibited increased liver weight (56.8 and 567.8 mg/kg-day) and reduced body weight (567.8 mg/kg-day; (ECHA, 1995); see Table 3). Another short-term study (10-days exposure to 25 mg/kg-d 6:2 FTS via oral gavage) in male Sprague-Dawley rats similarly demonstrated a 12% increase in relative liver weight (ECHA, 2020d) (Table 3).

Three separate ECHA reports were derived from the same 1-generation reproductive toxicity study using male and female Wistar rats exposed to 0, 5, 15, or 45 mg/kg-day 6:2 FTS via oral gavage from 10 weeks prior to mating through the end of lactation (ECHA, 2018a, b, c). Adult P0 male rats exposed to 45 mg/kg-day 6:2 FTS exhibited elevated urea levels and kidney tubular dilation (5 of 12 rats; (ECHA, 2018b); see Table 3). Pregnant P0 dams exhibited decreased body weight (45 mg/kg-day), decreased heart weight (15 and 45 mg/kg-day), and mild to moderate kidney tubular dilation (1 of 12 dams in the 45 mg/kg group; (ECHA, 2018a)). No developmental or teratogenic effects of the F1 offspring were reported in this study (i.e., offspring survival, anogenital distance, nipple retention; see Table 3) (ECHA, 2018c).

In summary, the strongest evidence available from animal studies suggests that the immune system and liver may be targets for 6:2 FTS, though the evidence is relatively limited. The evidence for immune effects is limited to one 16-week study in P0 male and female white-footed mice that showed decreased spleen PFCs in response to SRBCs, suggestive of immunosuppression of the humoral response (Bohannon et al., 2023). The findings of decreased spleen PFCs in response to SRBCs is consistent with studies of other PFAS, including PFOS (Peden-Adams et al., 2008; Dong et al., 2009) and is consistent with prior studies reporting on other immunosuppressive effects of PFAS (Woodlief et al., 2021; Dewitt et al., 2019; Antoniou et al., 2022) and human health toxicity assessments evaluating the immunotoxic effects of other PFAS (EPA Office of Water Human Health Toxicity Values for HFPO-DA (U.S. EPA, 2021c), PFOS (U.S. EPA, 2024b), and PFOA (U.S. EPA, 2024c); ATSDR Toxicological Profile for Perfluoroalkyls (ATSDR, 2021)).

The evidence for liver effects is limited to one 28-day study in male mice that showed increased relative liver weight (with no effect on body weight), increased serum levels of AST and ALB, and less reliable histopathological findings reported as increases in hepatocellular hypertrophy and necrosis and increased levels of pro-inflammatory cytokines in the liver (TNFα, IL-6) (Sheng et al., 2017). The statistically significant effect size for increased liver weight (22% increase relative to controls) is interpreted as biologically significant. The modest increase in AST may be coherent with liver hypertrophy, but the more reliable measure of ALT was not altered. Though the liver histopathology evidence is low confidence, the study reported findings of hepatocellular hypertrophy and necrosis. Although uncertainties remain, the constellation of hepatic changes induced by 6:2 FTS in this study are generally consistent with those observed for other PFAS (EPA IRIS Assessment for PFBA (U.S. EPA, 2022a), EPA IRIS Assessment for PFHxA (U.S. EPA, 2023), EPA Office of Water Human Health Toxicity Values for HFPO-DA (U.S. EPA, 2021c), PFOS (U.S. EPA, 2024b), and PFOA (U.S. EPA, 2024c); ATSDR Toxicological Profile for Perfluoroalkyls (ATSDR, 2021)). Evidence from the low confidence reports by ECHA similarly showed increased liver weight (ECHA, 1995, 2020d), increased serum AST and ALB (ECHA, 1995), and histopathological changes in liver hepatocytes including hepatocellular hypertrophy, reduced hepatocellular nuclei, and necrosis (ECHA, 1995).

Table 3 Available Oral Toxicity Data for 6:2 FTS

Species (strain), study details | Dose (mg/kg-d) | Critical effects | Other effects | Reference, confidence
Short term
Rat, Crl:CD(SD); Male; 10-d; Oral gavage | 0, 25 | 12% increase in relative liver weight in 25 mg/kg-d group. | N/A | ECHA (2020d); Low
Mouse, Crl:CD-1(ICR)BR; Male; 14-d; Diet | 0, 0.57, 5.68, 56.8, 567.7 | Increased relative liver weight (56.8 and 567.7 mg/kg-d) and absolute liver weight (56.8 and 567.7 mg/kg-d). | Decreased body weight (567.7 mg/kg-d). | ECHA (1995); Low
Mouse, Crl:CD-1(ICR)BR; Male; 28-d; Oral gavage | 0, 5 | Increased relative liver weight accompanied by hepatocyte lesions (hepatocellular hypertrophy, reduced hepatocellular nuclei, and necrosis) and serum markers of liver injury (increased serum AST and ALB). | N/A | Sheng et al. (2017); Medium for relative liver weight and clinical chemistry; Low for histopathology
Subchronic
Rat, Wistar Han; IGS Male 90-d (premating-mating); Female 123-d (premating-LD13); Oral gavage | 0, 5, 15, 45 | N/A | Elevated mean urea levels (45 mg/kg-d males), renal tubular dilatation (42% of 45 mg/kg-d males and 8% of 45 mg/kg-d females). | ECHA (2018b); Low
Chronic/Carcinogenicity
No data available.
Reproductive/Developmental
Mouse, White-footed; P0 Male 112-d; P0 Female 112-d; Oral gavage | 0, 0.2, 1, 5, 25 | Decreased sheep red blood cell-induced plaque forming cells in the spleen (−59% and −87% in 5 and 25 mg/kg-d males, respectively and −57% and −72% in 5 and 25 mg/kg-d females). | Increased spleen weight in males (1, 5, and 25 mg/kg-d). | Bohannon et al. (2023); Medium
Rat, Wistar Han; IGS; Male 90-d (premating-mating); Female 123-d (premating-LD13); Oral gavage | 0, 5, 15, 45 | N/A | No effects reported. | ECHA (2018c); Low
Rat, Wistar Han; IGS Male 90-d (premating-mating); Female 123-d (premating-LD13); Oral gavage | 0, 5, 15, 45 | N/A | Decreased body weight (45 mg/kg-d P0 dams), slightly decreased heart weight (15 mg/kg-d and 45 mg/kg-d P0 dams), mild to moderate renal tubular dilatation (8% of 45 mg/kg-d P0 dams). | (ECHA, 2018a); Low for all outcomes except thyroid hormone measures, which were considered Uninformative

Note: mg/kg-d in the study by ECHA (1995) was estimated based on molecular weight and standard body weights and food consumption from dietary exposure levels of 0, 3, 30, 300, and 3000 ppm.

## Other Evidence

A total of 95 studies with supplemental information on 6:2 FTS were identified (Figure 1). These studies did not meet PECO criteria but reported on mechanistic evidence, genotoxicity, adsorption/distribution/metabolism/excretion (ADME), non-mammalian models, non-oral routes of exposure, and exposure only. The supplemental information most useful to drawing interpretations for this assessment was identified in 26 of the supplemental studies and are summarized first (i.e., genotoxicity evidence; ADME/pharmacokinetic information), followed by a summary of the other relevant supplemental information (i.e. mechanistic).

### Genotoxicity Evidence

Table 4 Summary of 6:2 FTS Genotoxicity Studies

Endpoint | Test system | Concentrations tested | Results without activation^a^ | Results with external activation^a^ | References
Bacterial Reverse Mutation Assay | Salmonella typhimurium (TA 1535, TA 1537, TA 98, TA 100, and TA 102) | 0, 312.5, 625, 1250, 2500, 5,000 µg/plate | Negative for mutagenicity | Negative for mutagenicity | ECHA (2019d); ECHA (2020b) ^b^
Chromosomal Aberration | Chinese hamster Ovary cells | 0, 12.5, 25, 50, 100, 150, 200, 250, 300 µg/mL | Positive for induction of structural chromosomal aberrations Negative for induction of numerical chromosomal aberrations | Positive for induction of structural chromosomal aberrations Negative for induction of numerical chromosomal aberrations | ECHA (2007a); ECHA (2020c) ^b^
Alkaline Comet Assay | Male Sprague Dawley Rat | 0, 500, 1,000, 2,000 mg/kg-d | Negative for induction of DNA damage in liver or stomach | N/A | ECHA (2019e);; ECHA (2015) ^b^
Unscheduled DNA Synthesis | Male Sprague Dawley Rat | 0, 500, 1,000, 2,000 mg/kg-d | Negative | N/A | ECHA (2007b);; ECHA (2007d) ^b^
Mammalian Erythrocyte Micronucleus Test | Male and Female ICR Mice | 0, 500, 1,000, 2,000 mg/kg-d | Negative | N/A | ECHA (2007c); ECHA (2007f) ^b^
Mammalian Bone Marrow Chromosome Aberration Test | Male and Female ICR Mice | 0, 500, 1,000, 2,000 mg/kg-d | Negative | N/A | ECHA (2019f); ECHA (2007e) ^b^

a N/A = not applicable.

b Results correspond to the potassium salt form of 6:2 FTS (CASRN: 59587-38-1)

The genotoxicity of 6:2 FTS was assessed by ECHA in in vitro and in vivo assays (see Table 4). Overall, 6:2 FTS was positive for inducing structural chromosomal aberrations in Chinese Hamster Ovary (CHO) cells but was negative in all other genotoxicity assays (see Table 4).

### Pharmacokinetic Information

Absorption and distribution data specific to 6:2 FTS are limited to preliminary pharmacokinetic data in rats following oral gavage obtained from ECHA dossiers (ECHA, 2019b, 2020d). Absorption of 6:2 FTS was evident in male Sprague-Dawley rats following 10 days of oral exposure to 25 mg/kg-d 6:2 FTS based on the quantification of fluorine in blood, liver, and fat (ECHA, 2020d). Distribution data specific to 6:2 FTS were limited to tissue:plasma ratios reported by ECHA (it should be noted individual tissue measurements were not reported, only the ratios) (ECHA, 2019b). Tissue:plasma ratios for liver and adipose were determined for male and female Sprague-Dawley rats following a single oral gavage exposure to either 10 or 30 mg/kg 6:2 FTS (ECHA, 2019b). For females, no tissue:plasma ratios were able to be calculated as all adipose and plasma values were below the limit of quantitation (LOQ). For males, the adipose:plasma ratio was <0.1 at the 10 mg/kg dose and 0.1 at the 30 mg/kg dose and the liver:plasma ratio was 3.0 at the 10 mg/kg dose and 3.1 at the 30 mg/kg dose.

6:2 FTS was not metabolized in in vitro rat liver S9 studies reported by ECHA (2019a). When compared with PFOA and PFOS, the serum accumulation of 6:2 FTS is 3-7 times lower following 28 days oral exposure to 5 mg/kg-d (Table 5). However, liver accumulation of 6:2 FTS was much greater than either PFOA or PFOS, particularly when the liver:serum accumulation ratios were compared. In mice, 6:2 FTS was shown to accumulate 10 times more in the liver than in the serum, whereas PFOS accumulated to a similar extent between serum and liver and PFOA accumulates about 1.7 times more in the liver than the serum. These serum and liver accumulation differences have been observed with other hepatotoxic non-legacy PFAS, including GenX chemicals (Blake et al., 2022).

Table 5 Serum and liver concentrations of 6:2 FTS compared with PFOA and PFOS following 28 days oral administration of 5 mg/kg-d in male mice

PFAS (Reference) | PFAS in serum (µg/mL) | PFAS in liver (µg/g) | Liver:Serum ratio
6:2 FTS Sheng et al. (2017) | 18.52 | 194.44 | 10.50:1
PFOA Yan et al. (2014) | 56.24 | 98.08 | 1.74:1
PFOS Sheng et al. (2017) | 125.4 | 145.88 | 1.16:1

In male Sprague-Dawley rats, 65-68% of the administered 6:2 FTS was recovered in urine 96 hours after a single oral gavage dose, with urinary excretion half-lives of 20.9 and 23.75 hours via NMR and LC/MS, respectively (ECHA, 2019c). Sex-specific and species/strain-specific differences in 6:2 FTS half-life is not known. The human half-life of 6:2 FTS is not known. In male rats, the half-life of PFOS is 35-53 days while the half-life of 6:2 FTS is ~22 hours, suggesting 6:2 FTS may be more rapidly eliminated in humans than PFOS.

### Other Supplemental Information

Of the remaining mechanistic studies, two were determined to not contain data relevant to 6:2 FTS (Rand and Mabury, 2012; Bangma et al., 2020). Other mechanistic evidence suggests 6:2 FTS exposure induces inflammation, including in the liver, and disrupts liver gene expression. Sheng et al., (2017) reported increased cytokines in serum and liver (TNFα, ILβ, IL-10), and increased expression of proteins indicative of an inflammatory response (IkBa, NFkB/p65, NRF-2, TRL-4, and TNFR-2) in male CD-1 mice after 28 days of oral exposure to 6:2 FTS at a dose of 5 mg/kg-day. Sheng et al., (2017) also reported 412 genes were differentially expressed in the liver following exposure to 6:2 FTS, with gene expression changes consistent with biological processes related to inflammation (N = 74 genes), necrosis (N = 23 genes), apoptosis (N = 90 genes), and immune response (N = 23 genes). Notably, however, gene expression changes in the liver induced by 6:2 FTS were PPARα-independent. Sheng et al., (2018) used human liver HL-7702 cells and reported exposure to 6:2 FTS was slightly more cytotoxic in this cell line compared with PFOS and that 6:2 FTS exposure in these cells disrupted cell cycle, increased expression of fatty acid translocase (CD36), cyclin dependent kinase 4 (CDK4), and MYC proto-oncogene, bHLH transcription factor (MYC), and exhibited weak binding to fatty acid binding protein (FABP). In a study using five-donor pooled human hepatocytes, in vitro exposure to 6:2 FTS significantly increased lipid accumulation and significantly dysregulated expression of genes involved in lipid metabolism (e.g., BDH2, PCK2), transport (e.g., MTTP), and synthesis/storage (e.g., SREBF1, FASN), cholesterol metabolism (e.g., ABCA1, HMGCS1), antioxidant response (e.g., GSTA1 SOD1), and xenobiotic metabolism (e.g., NR1L2, SULT2A1) (Marques et al., 2022). In human liver microsomes, 6:2 FTS inhibited activity of carboxylesterase 1 (CES1), an enzyme primarily expressed in the liver and involved in energy homeostasis processes, to a greater extent than PFOS (Liu et al., 2020). In insect cells expressing 11 recombinant human UDP-glucuronosyltransferase (UGT) isoforms, 6:2 FTS exposure did not exhibit inhibitory effects (Liu et al., 2019). In addition to mechanistic evidence for 6:2 FTS-induced liver effects, studies reported mechanistic evidence related to several other biological functions. Exposure of zebrafish (Danio rerio) embryos to 6:2 FTS induced oxidative stress, inflammation, and immunotoxicity (Zhang et al., 2023) but did not affect swim bladder inflation (Fey et al., 2022). In an in vitro thyroid hormone bioassay system, 6:2 FTS was found to be 100 times less potent than PFOS (Behnisch et al., 2021). Ex vivo exposure of mouse plasma to 6:2 FTS did not affect activation of the plasma kallikrein-kinin signaling cascade, which is involved in cardiovascular and cerebrovascular function (Liu et al., 2017).