# METHODS

For this assessment, the general systematic review steps common to other human health related ORD assessments (e.g., in Integrated Risk Information System [IRIS]) were applied, including the development of populations, exposures, comparators, and outcomes (PECO) criteria for inclusion and literature search and screening of multiple databases for relevant articles.

Briefly, the systematic review methods used here are consistent with the Office of Research and Development Staff Handbook for Developing Integrated Risk Information System Assessments (Version 2.0, referred to as the “IRIS Handbook”) (U.S. EPA, 2022b). These methods have been reviewed by the National Academies of Sciences, Engineering, and Medicine (NASEM, 2018) and used in other peer-reviewed systematic reviews (Yost et al., 2019; Radke et al., 2018). As the purpose of this human health toxicity value (HHTV) assessment is to develop scientifically supported chronic toxicity values, where data are available and meeting the identified needs of the requestors (see Background section), the systematic review methods applied in this HHTV assessment are more narrowly scoped than those applied in typical IRIS assessments. For example, less emphasis is placed on providing definitive judgements of the integrated weight of evidence.

The systematic review methods used to collect epidemiological and toxicological evidence for 6:2 FTS are described in detail in Carlson et al. (2022), Carlson et al. (2024) and Radke et al. (2022), as well as Appendix A. 6:2 FTS was included in the list of 150 PFAS described in those materials, and for the purposes of this summary, the 6:2 FTS-specific results found were isolated as a result of the outlined processes. Literature search updates for 6:2 FTS were conducted in November 2022 and September 2023 to identify relevant literature published after publication of the PFAS 150 evidence map. These methods are also described in Appendix A. In addition to database searches, nonconfidential business information (non-CBI) industry studies were identified that included toxicological evidence for 6:2 FTS. Since February 2020, EPA has requested, pursuant to Section 308 of the Act, 33 U.S.C. § 1318, that 3M provide information on its use and possible release of certain PFAS, such as 6:2 FTS. Under that agreement, 3M shared internal files of memos, reports, interim or final data summaries or studies, correspondence, etc. that included non-CBI content for 6:2 FTS. The available information for 6:2 FTS received from 3M was screened for relevance to the PECO criteria (Figure 1). Literature identified as relevant from the database searches or non-CBI data repositories underwent screening for PECO relevance using the program DistillerSR and those meeting PECO criteria underwent data extraction and study evaluation (see documentation in Health Assessment Workspace Collaborative [HAWC (https://hawc.epa.gov/assessment/100500285/)]).