# INTRODUCTION

Per- and polyfluoroalkyl substances (PFAS) are a large group of anthropogenic chemicals that include the well-known C8 species perfluorooctanoic acid (PFOA), perfluorooctane sulfonic acid (PFOS), and thousands of other structurally diverse fluorinated species. The universe of environmentally relevant PFAS, including parent chemicals, metabolites, and abiotic degradants, is greater than 12,000 substances.^1^

1 https://comptox.epa.gov/dashboard/chemical_lists/PFASMASTER.

PFAS have strong, stable carbon-fluorine (C-F) bonds, making them resistant to hydrolysis, photolysis, microbial degradation, and metabolism (Buck et al., 2011; Beach et al., 2006; Ahrens, 2011). The chemical structures of PFAS make them repel water and oil, remain chemically and thermally stable, and exhibit surfactant properties; these properties are what make PFAS useful for commercial and industrial applications and purposes, but also contribute to their persistence in the human body and the environment (Calafat et al., 2007; Calafat et al., 2019). Due to their widespread use, physicochemical properties, persistence, and bioaccumulation potential, many PFAS occur in exposure media (e.g., air, water, ice, sediment), and in tissues and blood of aquatic and terrestrial organisms, and humans.

Humans are widely exposed to PFAS (Sunderland et al., 2019), and PFAS have been shown to pose ecological and human health hazards (Hekster et al., 2003; Fenton et al., 2021; DeWitt, 2015). The available toxicity data, however, are limited to relatively few well-studied PFAS (e.g., PFOA, PFOS, GenX chemicals, PFBS, and others). Most of the PFAS structures listed in EPA’s CompTox Chemicals Dashboard^1^ are data-poor, having little to no data that might inform potential human health effects. One of these PFAS, 6:2 fluorotelomer sulfonic acid (6:2 FTS; CASRN 27619-97-2), is used as a replacement for perfluorooctanoic acid (PFOS) in aqueous film-forming foam (AFFF) (Shojaei et al., 2022) and the chromium electroplating industry (MI DEGLE, 2020) and has been detected in surface and waste waters in or around industrial facilities. 6:2 FTS, and its related salts, are all members of the overall PFAS class. This EPA Office of Research and Development human health toxicity value (HHTV) assessment applies to the acid form (6:2 fluorotelomer sulfonic acid; CASRN 27619-97-2), the anionic form (6:2 fluorotelomer sulfonate; CASRN 425670-75-3), and associated salts (including nonmetal or alkali metal salts) of 6:2 FTS that would be expected to fully dissociate in aqueous solutions with pH ranging from 4–9 (e.g., in the human body), which includes the potassium (CASRN 59587-38-1), ammonium (CASRN 59587-39-2), and sodium (CASRN 27619-94-9) salt forms. The synthesis of evidence and toxicity value derivation presented in this assessment focuses on the 6:2 fluorotelomer sulfonate potassium salt and 6:2 fluorotelomer sulfonate ammonium salt given the currently available toxicity data. The molecular structure, formula, and experimental or predicted physicochemical properties of 6:2 FTS and the potassium and ammonium salts are presented in Table 1.

Table 1 Physical and Chemical Properties of 6:2 FTS and Related Compounds

Property or endpoint (unit) | 6:2 FTS acid | 6:2 FTS anion | 6:2 FTS potassium salt | 6:2 FTS ammonium salt | 6:2 FTS sodium salt
Structure | chemical structure | chemical structure | chemical structure | chemical structure | chemical structure
CASRN | 27619-97-2 | 425670-75-3 | 59587-38-1 | 59587-39-2 | 27619-94-9
DTXSID | 6067331 (https://comptox.epa.gov/dashboard/chemical/details/DTXSID6067331) | 40873417 (https://comptox.epa.gov/dashboard/chemical/properties/DTXSID40873417) | 50880511 (https://comptox.epa.gov/dashboard/chemical/details/DTXSID50880511) | 10880512 (https://comptox.epa.gov/dashboard/chemical/details/DTXSID10880512) | 50896637 (https://comptox.epa.gov/dashboard/chemical/details/DTXSID50896637)
Synonyms | 1H,1H,2H,2H-Perfluorooctanesulfonic acid; 1-Octanesulfonic acid,; 3,3,4,4,5,5,6,6,7,7,8,8-tridecafluoro-2-(Perfluorohexyl)ethane-1-sulfonic acid; 3,3,4,4,5,5,6,6,7,7,8,8,8-Tridecafluoro-1-octanesulfonic acid; 3,3,4,4,5,5,6,6,7,7,8,8,8-Tridecafluoroctansulfonsaure; 3,3,4,4,5,5,6,6,7,7,8,8,8-Tridecafluorooctane-1-sulfonic acid; 3,3,4,4,5,5,6,6,7,7,8,8,8-Tridecafluorooctanesulfonic acid; 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid; 6:2 Fluorotelomer sulfonic acid; Acide 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulfonique; Fluorotelomer sulfonic acid 6:2 | 1H,1H,2H,2H-perfluorooctane sulfonate 1-Octanesulfonato, 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluoro-, ion(1-); 1-Octanesulfonic acid, 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluoro-, ion(1-); 2-(Perfluorohexyl)ethane-1-sulfonate; 3,3,4,4,5,5,6,6,7,7,8,8,8-Tridecafluorooctane-1-sulfonatato; 3,3,4,4,5,5,6,6,7,7,8,8,8-Tridecafluorooctane-1-sulfonate | 1-Octanesulfonic acid, 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluoro-, potassium salt (1:1); Potassium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctane-1-sulfonate; Potassium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonate; 1-Octanesulfonic acid, 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluoro-, potassium salt | 1-Octanesulfonic acid, 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluoro-, ammonium salt; 6:2 Fluorotelomer sulphonate ammonium; Ammonium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctane-1-sulfonate; Ammonium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonate | 1-Octanesulfonic acid, 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluoro-, sodium salt (1:1); 6:2 Fluorotelomer sulfonate sodium salt; Sodium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctane-1-sulfonate; Sodium 1H,1H,2H,2H-perfluorooctanesulfonate
Molecular formula | C_8_H_5_F_13_O_3_S | C_8_H_4_F_13_O_3_S | C_8_H_4_F_13_KO_3_S | C_8_H_8_F_13_NO_3_S | C_8_H_4_F_13_NaO_3_S
Molecular wt. (g/mol) | 428.16 | 427.16 | 466.25 | 445.2 | 450.15
Melting pt. (°C) | 69.1^a^ | 126^a^ | 198^a^ | 179^a^ | 186^a^
Boiling pt. (°C) | 238^a^ | 219^a^ | 219^a^ | 219^a^ | 219^a^
Density (g/cm^3^) | 1.68^a^ | 1.71^a^ | 1.71^a^ | 1.71^a^ | 1.71^a^
pH (unitless) | NA | NA | NA | NA | NA
pK_a_ (unitless) | NA | NA | NA | NA | NA
Vapor pressure (mmHg) | 8.32 × 10^−7a^ | 8.32 × 10^−7a^ | 8.32 × 10^−7a^ | 8.32 × 10^−7a^ | 8.32 × 10^−7a^
Henry’s Law constant (atm-m^3^/mole) | 1.82 × 10^−10a^ | 1.82 × 10^−10a^ | 1.82 × 10^−10a^ | 1.82 × 10^−10a^ | 1.82 × 10^−10a^,^a^
Water solubility (mol/L) | 8.55 × 10^−4a^ | 1.70 × 10^−3a^ | 1.70 × 10^−3a^ | 1.70 × 10^−3a^ | 1.70 × 10^−3a^
Octanol-water partition constant (log K_ow_) | 3.39^a^ | 3.23^a^ | 2.11^a^ | 3.48^a^ | 2.38^a^
Bioconcentration factor (unitless) | 6.03^a^ | 6.03^a^ | 6.03^a^ | 6.03^a^ | 6.03^a^

Unless otherwise noted, data were extracted from the U.S. EPA CompTox Chemicals Dashboard, accessed December 12th, 2024 (6:2 Fluorotelomer sulfonic acid [CASRN 27619-97-2] https://comptox.epa.gov/dashboard/chemical/details/DTXSID6067331, 6:2 Fluorotelomer sulfonate [CASRN 425670-75-3] https://comptox.epa.gov/dashboard/chemical/properties/DTXSID40873417, 6:2 Fluorotelomer sulfonate potassium salt [CASRN 59587-38-1] https://comptox.epa.gov/dashboard/chemical/details/DTXSID50880511, 6:2 Fluorotelomer sulfonate ammonium salt [CASRN 59587-39-2] https://comptox.epa.gov/dashboard/chemical/details/DTXSID10880512, 6:2 Fluorotelomer sulfonate sodium salt [CASRN 27619-94-9] https://comptox.epa.gov/dashboard/chemical/details/DTXSID50896637. All values are experimental averages unless otherwise specified.

a Predicted average values shown.