# BACKGROUND

The U.S. Environmental Protection Agency (U.S. EPA) Office of Research and Development (ORD) under the Health and Environmental Risk Assessment (HERA) National Research Program has developed a human health toxicity value (HHTV) assessment for 6:2 fluorotelomer sulfonic acid (6:2 FTS; CASRN 27619-97-2). This HHTV assessment was developed in response to a request from the EPA Office of Land and Emergency Management (OLEM), Office of Air and Radiation (OAR), Office of Enforcement Compliance and Assurance (OECA), Office of Children’s Health Protection (OCHP), and EPA Region 5. Now final, this document may be used to support decisions to protect human health. The assessment provides qualitative and quantitative toxicity information that can be used, along with exposure information and other important considerations, to assess potential health risks to determine if, and when, taking action to address this chemical is appropriate.

The purpose of this HHTV assessment is to provide support for risk-based decision-making pertaining to chronic exposures to 6:2 FTS at sites or geographic locations or in specified environmental media (e.g., water, soil, air). To the extent possible based on the currently available evidence, the objective of this assessment is to present the major conclusions reached in hazard identification and derivation of human health toxicity values and to characterize the overall confidence in these conclusions and values. This assessment is not intended to represent a comprehensive treatise on the chemical. For example, less emphasis is placed on providing definitive judgements of the integrated weight of evidence. Several factors are considered during scoping and problem formulation activities to ensure the assessment appropriately fits the intended purpose. These factors include the anticipated end-user need, peer-review and public comment requirements, and anticipated availability of hazard and dose-response evidence. As needed, factors are assessed and informed through direct conversations with the requesting office(s).

Noncancer and/or cancer toxicity values are derived (when supported by data) after a systematic review of the relevant scientific literature, an evaluation of available hazard and dose-response information using established EPA guidelines on human health risk assessment, and appropriate internal EPA and external independent peer review.