# APPENDIX B BENCHMARK DOSE MODELING RESULTS

## Modeling Procedure for Continuous Noncancer Data

Benchmark dose (BMD) modeling of continuous data is conducted with EPA’s BMD Software (BMDS, Version 3.3). All continuous models available within the software are fit using a benchmark response (BMR) of 1 standard deviation (SD) relative risk or 10% extra risk when a biologically determined BMR is available (e.g., BMR of 10% relative deviation [RD] for body weight based on a biologically significant weight loss of 10%), as outlined in the Benchmark Dose Technical Guidance (U.S. EPA, 2002). A BMR of 1 SD was applied. An adequate fit is judged on the basis of a χ2 goodness-of-fit p-value (p > 0.1), the magnitude of the scaled residuals near the BMR, and a visual inspection of the model fit. In addition to these three criteria for judging adequacy of model fit, whether the variance across dose groups is homogeneous is determined. If a homogeneous variance model is deemed appropriate on the basis of the statistical test provided by BMDS (i.e., Test 2), the final BMD results are estimated from a homogeneous variance model. When the test for homogeneity of variance is rejected (p < 0.1), the model is rerun with the variance modeled as a power function of the mean to account for this nonhomogeneous variance. If this nonhomogeneous variance model does not adequately fit the data (i.e., Test 3; p < 0.1), the data set is considered unsuitable for BMD modeling. Among all models providing adequate fit, the lowest BMD lower confidence limit (BMDL) or the benchmark concentration lower confidence limit (BMCL) is selected if the BMDL or BMCL estimate from different models vary by greater than threefold. Otherwise, the BMDL or BMCL from the model with the lowest Akaike’s information criterion (AIC) is selected as a potential point of departure (POD) from which to derive the oral reference dose or inhalation reference concentration (RfD or RfC).

## Model Predictions for Decreased Spleen Plaque-Forming Cells (PFCs) in Adult Male Mice (Bohannon et al., 2023)

The procedure outlined above for continuous data was applied to the data for decreased PFCs in adult male white-footed mice exposed to 6:2 FTS for 112 days via oral gavage (Bohannon et al., 2023). The BMD modeling results are summarized in Table B-1 and Figure B-1. The non-constant variance model provided adequate fit to the variance data, and adequate fit to the means was provided by some included models. The BMDLs for the models providing adequate fit were sufficiently close (differed by <threefold), so the model with the lowest AIC (Exponential 5) was selected. For decreased spleen PFCs, the BMDL_1SD_ of 1.5 mg/kg-day from this model was selected.

Table B-1 BMD Modeling Results for Increased Relative Liver Weight in Adult Male White Footed Mice Exposed to 6:2 FTS for 112 Days via Oral Gavage^a^

Model | df | χ2 Goodness-of-Fit p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_1SD_ (mg/kg-d) | BMDL_1SD_ (mg/kg-d)
Exponential 3 | 3 | <0.001 | −5.363 | 1325.425 | 3.004 | -
Exponential 5 * | 1 | 1 | 0.602 | 1257.117 | 2.762 | 1.507
Hill | 1 | 1 | 0.503 | 1257.142 | 2.694 | 1.782
Polynomial 2 | 3 | <0.001 | −6.064 | 1338.848 | 8.755 | 7.559
Polynomial 3 | 3 | 0 | - | 1629.534 | - | -
Polynomial 4 | 2 | 0 | 4.25 | 1626.775 | 267.168 | -
Power | 3 | <0.001 | −5.8 | 1339.019 | 9.101 | 7.524
Linear | 3 | 0 | - | 1625.58 | - | -

a (Bohannon et al., 2023)

b Values <0.10 failed to meet conventional goodness-of-fit criteria.

* Selected model (bold). Lowest AIC among models with adequate fit was selected (Exponential 5).

AIC = Akaike’s information criterion; BMD = maximum likelihood estimate of the dose associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 10RD = dose associated with 10% relative deviation from the control); BMR = benchmark response; df = degree(s) of freedom.

Figure B-1 Fit of Exponential 5 Model to Data for Decreased Spleen PFCs in Adult Male White Footed Mice Exposed to 6:2 FTS for 112 Days via Oral Gavage (Bohannon et al., 2023)

Model output for Figure B-1:

Benchmark Dose
BMD | 2.76173
BMDL | 1.50664
BMDU | 4.73982
AIC | 1257.12
Log Likelihood | 622.559
P-value | 1
D.O.F. | 1

Model Parameters
# of parameters | 6
Variable | Estimate
a | 1264.23
b | 0.198828
c | 0.152089
d | 2.34214
rho | 2.65271
log-alpha | −8.04034

Goodness of Fit
Dose | Size | Estimated Mean | Calc Mean | Obs Mean | Estimated SD | Calc SD | Obs SD | Scaled Residual
0 | 21 | 1264.23 | 1450 | 1450 | 233.443 | 197 | 197 | 3.64675
0.2 | 21 | 1263.67 | 1040 | 1040 | 233.305 | 123 | 123 | −4.39327
1 | 21 | 1240.12 | 1270 | 1270 | 227.556 | 183 | 183 | 0.601725
5 | 19 | 592.052 | 596 | 596 | 85.3477 | 76.1 | 76.1 | 0.20162
25 | 18 | 192.275 | 192 | 192 | 19.2022 | 20.8 | 20.8 | −0.0607624

Likelihoods of interest
Model | Log Likelihood | # of Parameters | AIC
A1 | −633.443 | 6 | 1278.89
A2 | −597.669 | 10 | 1215.34
A3 | −632.134 | 7 | 1278.27
Fitted | −622.559 | 6 | 1257.12
Reduced | −757.275 | 2 | 1518.55

Tests of Interest
Test | −2*Log(Likelihood Ratio) | Test df | P-value
1 | 319.212 | 8 | 0
2 | 71.5481 | 4 | <0.0001
3 | 68.929 | 3 | <0.0001
4 | 0 | 1 | 1

## Model Predictions for Decreased Spleen Plaque-Forming Cells (PFCs) in Adult Female Mice (Bohannon et al., 2023)

The procedure outlined above for continuous data was applied to the data for decreased PFCs in adult female white-footed mice exposed to 6:2 FTS for 112 days via oral gavage (Bohannon et al., 2023). The BMD modeling results are summarized in Table B-2 and Figure B-2. The non-constant variance model provided adequate fit to the variance data, and adequate fit to the means was provided by some included models. The BMDLs for the models providing adequate fit were sufficiently close (differed by <threefold), so the model with the lowest AIC (Hill) was selected. For decreased spleen PFCs, the BMDL_1SD_ of 2.2 mg/kg-day from this model was selected.

Table B-2 BMD Modeling Results for Increased Relative Liver Weight in Adult Female White Footed Mice Exposed to 6:2 FTS for 112 Days via Oral Gavage^a^

Model | df | χ2 Goodness-of-Fit p-Value^b^ | Scaled Residual at Dose Nearest BMD | AIC | BMD_1SD_ (mg/kg-d) | BMDL_1SRD_ (mg/kg-d)
Exponential 3 | 2 | −1 | 0 | - | - | -
Exponential 5 | 1 | 1 | 0.526 | 1308.122 | 4.331 | 2.554
Hill * | 1 | 1 | 0.526 | 1308.122 | 3.885 | 2.236
Polynomial 2 | 3 | 0 | 4.271 | 1640.761 | 1650.935 | -
Polynomial 3 | 2 | 0 | 4.102 | 1629.556 | 346.838 | -
Polynomial 4 | 2 | 0 | 4.309 | 1643.688 | 695.177 | 457.72
Power | 3 | <0.001 | −6.443 | 1418.887 | 12.761 | 10.821
Linear | 3 | <0.001 | −6.417 | 1418.881 | 12.841 | 10.824

a (Bohannon et al., 2023)

b Values <0.10 failed to meet conventional goodness-of-fit criteria.

* Selected model (bold). Lowest AIC among models with adequate fit was selected (Exponential 5).

AIC = Akaike’s information criterion; BMD = maximum likelihood estimates of the dose associated with the selected BMR; BMDL = 95% lower confidence limit on the BMD (subscripts denote BMR: i.e., 10RD = dose associated with 10% relative deviation from the control); BMR = benchmark response; df = degree(s) of freedom.

Figure B-2 Fit of Hill Model to Data for Decreased Spleen PFCs in Adult Female White Footed Mice Exposed to 6:2 FTS for 112 Days via Oral Gavage (Bohannon et al., 2023)

Model output for Figure B-2:

Benchmark Dose
BMD | 3.88538
BMDL | 2.23648
BMDU | 4.18194
AIC | 1308.12
Log Likelihood | 648.061
P-value | 1
D.O.F. | 1

Model Parameters
# of parameters | 6
Variable | Estimate
g | 1031.91
v | −769.915
k | 4.24954
n | 10.277
rho | 2.27694
alpha | 0.00660865

Goodness of Fit
Dose | Size | Estimated Mean | Calc Mean | Obs Mean | Estimated SD | Calc SD | Obs SD | Scaled Residual
0 | 22 | 1031.91 | 908 | 908 | 219.28 | 123 | 123 | −2.65054
0.2 | 21 | 1031.91 | 1070 | 1070 | 219.28 | 197 | 197 | 0.795911
1 | 20 | 1031.91 | 1120 | 1120 | 219.28 | 287 | 287 | 1.79647
5 | 21 | 383.837 | 392 | 392 | 71.1264 | 48.5 | 48.5 | 0.525914
25 | 19 | 262 | 258 | 258 | 46.0489 | 56.5 | 56.5 | −0.378587

Likelihoods of interest
Model | Log Likelihood | # of Parameters | AIC
A1 | −671.309 | 6 | 1354.62
A2 | −631.756 | 10 | 1283.51
A3 | −669.836 | 7 | 1353.67
Fitted | −648.061 | 6 | 1308.52
Reduced | −760.069 | 2 | 1524.14

Tests of Interest
Test | −2*Log(Likelihood Ratio) | Test df | P-value
1 | 256.626 | 8 | 0
2 | 79.1053 | 4 | <0.0001
3 | 76.1595 | 3 | <0.0001
4 | 0 | 1 | 1