# Acknowledgments

We thank Catherine McKeon, Ph.D., from the National Institute for Diabetes and Digestive and Kidney Diseases, NIH, for her support and guidance.

We are grateful to the following individuals who kindly reviewed the content:

Beena Akolkar, Ph.D., National Institute for Diabetes and Digestive and Kidney Diseases, NIH

Elizabeth Barrett-Connor, M.D., Professor and Chair of the Department of Family and Preventive Medicine, and Chief, Division Of Epidemiology, University of California San Diego School of Medicine

Inês Barroso, Ph.D., Wellcome Trust Sanger Institute, UK

Nancy Cox, Ph.D., Associate Professor, Department of Human Genetics, University of Chicago

Stefan Fajans, M.D., Professor Emeritus, Department of Internal Medicine, University of Michigan

Steven Gabbe, M.D., Dean of the School of Medicine, Vanderbilt University

Kai Ge, Ph.D., National Institute for Diabetes and Digestive and Kidney Diseases, NIH

Anna Gloyn, Ph.D., Diabetes Research Laboratories, Nuffield Department of Clinical Medicine, University of Oxford

Mark Goodarzi, M.D., Cedars-Sinai Medical Center

Raghavan Raju, Ph.D., National Institute of Neurological Disorders and Stroke, NIH

Copy editor: Belinda Beck

Graphic design: Todd Groesbeck