# NIH Lectures

Winning at Losing: The Art and Science of Long-Term Weight Control (http://videocast.nih.gov/summary.asp?File=13061) Wednesday, February 15, 2006 Rena Wing, Ph.D., Brown Medical School Total Running Time: 00:53:15

Human Obesity and Insulin Resistance: Lessons from Experiments of Nature (http://videocast.nih.gov/summary.asp?Live=3465) Wednesday, June 29, 2005 Stephen O'Rahilly, M.D., Cambridge University Total Running Time: 01:00:11

Obesity: A Disease, Not a Character Flaw (http://videocast.nih.gov/Summary.asp?File=11764) Wednesday, January 14, 2004 Rudolph Leibel, M.D., Columbia University Total Running Time: 01:03:11

Diversity, Body Size and Diabetes: Genetics Without Genotyping (http://videocast.nih.gov/Summary.asp?File=12022) Wednesday, May 12, 2004 Elizabeth Barrett-Connor, M.D., University of California School of Medicine Total Running Time: 01:01:55

Type 2 Diabetes: the Good, the Bad, and the Ugly (http://videocast.nih.gov/summary.asp?Live=998) Wednesday, February 13, 2002 Robert A. Kreisberg, M.D., University of South Alabama Total Running Time: 01:03:45

You will need RealPlayer (http://www.real.com) to view these lectures.