# Data Points #20 Trends in the use of echocardiography, 2007 to 2011

Echocardiography is a widely used procedure among the Medicare-enrolled population. Each year approximately 20% of enrollees in the fee-for-service (FFS) system receive at least one cardiac echocardiogram.

The percentage of enrollees who receive echocardiography services varies widely by geography. Use of echocardiography rises with age until age 85, where it plateaus.

Allowed health care charges for echocardiography decreased from 2007 through 2011 while the number of procedures rose slightly and the average number of procedures per beneficiary per year remained stable.

Heart disease is the leading cause of death for men and women in the United States.1 In 2010, heart disease caused more than one in four, or 27 percent, of deaths among individuals age 65 or older.1 Echocardiography is a noninvasive test that uses ultrasound waves to create pictures of the heart.2 An echocardiogram allows clinicians to see the structures of the heart and to see the motion of blood through the heart.3 It is often used by clinicians to assess, diagnose, and manage heart problems such as abnormal valves, atrial fibrillation, heart disease, heart murmurs, and other issues.2, 3

Use of echocardiography increased dramatically in the United States from the 1990s to early 2000s. This increase occurred at a higher rate than non-cardiac imaging services, and was greater than might be expected relative to the aging of the population.4,5 Between 2000 and 2010, the volume of imaging services increased by 81 percent within Medicare.6 Also by 2010, echocardiography services made up 11 percent of Medicare spending on imaging services, accounting for approximately $1.2 billion in spending.6 The growth in use of echocardiography may have slowed in the late 2000s, but it remains an often used procedure.7,8

Efforts have been made to slow the increase in use of echocardiography through both payment and practice. The Deficit Reduction Act of 2005 reduced the Medicare payment for the technical com-ponent of echocardiography.9-11 In 2007, the Centers for Medicare & Medicaid Services (CMS) further reduced the amount paid for procedures beyond the index procedure on contiguous body parts during the same session.9 To address the possible overuse of echocardiography due to patterns of health care practice, a task force led by the American College of Cardiology Foundation (ACCF), American Society of Echocardiography (ASE), and specialty and subspecialty societies set out criteria for the appropriate use of echocardiography.12

They concluded that “appropriate echocardiograms are those that are likely to contribute to improving patients' clinical outcomes, and importantly, inappropriate use of echocardiography may be potentially harmful to patients and generate unwarranted costs to the health care system.”12 The criteria vary by previous service and clinical indication, but in general echocardiography testing is viewed as appropriate to assess conditions that have an indication of being cardiac in nature or to reassess diagnosed cardiac conditions when patients' symptoms have changed. Retesting to monitor a condition is considered inappropriate when patients' symptoms have not changed, there is no planned change in clinical management, and/or when fewer than one to three years have passed since the initial echocardiogram.12 One study estimates that the Deficit Reduction Act and the implementation of appropriateness criteria are two of multiple factors that have slowed the growth of echocardiography since 2005.^8^ However, the effect of these initiatives has not yet been quantified.

Understanding trends in the use of echocardiography remains complex (see Figures 1-3). It appears that the growth may be due to primary care providers who are increasingly ordering echocardiograms using equipment in their own offices rather than an increase in use by specialty providers such as cardiologists.6 The presence of testing equipment for echocardiography in primary care offices has been hypothesized to be a possible driver of this increase in use by primary care physicians. This relationship is still unclear - in the case of stress echocardiography, the relationship between the office location of testing material and increased cost of care after testing is modest.13 However, evidence indicates that physicians of various specialties tend to increase their use of tests when they are able to self-refer.14

Figure 1 Echocardiography services performed annually for the Medicare fee-for-service program, 2007-2011

Line graph showing the number of echocardiography services performed annually in Medicare. About 6.8 million echocardiography services were performed in 2007, increasing to about 7.1 million in 2011.

Figure 2 Eligible Medicare beneficiaries receiving one or more echocardiography services, by age, 2007-2011

Line graph of the percentage of eligible Medicare beneficiaries receiving one or more echocardiography service by age category. Beneficiaries age 80 and above have the highest percentage receiving echocardiography services at around 25%, while beneficiaries ages 65-69 have the lowest percentage at around 14% of beneficiaries receiving echocardiography services.

Figure 3 Eligible Medicare beneficiaries receiving one or more echocardiography service, by age, 2011

Bar chart showing the percentage of eligible Medicare beneficiaries receiving one or more echocardiography service by age category in 2011. The figure shows that the percent of beneficiaries receiving echocardiography services increases steadily from 13% in the 65-69 group to 26% in the 80-84 group, and plateaus at about 25% in the 85+ age group.

There is significant geographic variation in the use of echocardiography. Rates of echocardiography and noninvasive diagnostic imaging are lower in the Northern U.S. and higher in the Southeastern U.S.15, 16 Use of echocardiography is higher in urban areas than for patients in rural areas. This may be due to greater distance for those in rural areas to facilities offering echocardiography, suggesting that greater patient volume may be associated with the decision to invest in echocardiography equipment.16-18 Variations in the prevalence of heart disease also appear to contribute to geographic variations in use of echocardiography.6 Among patients who receive echocardiography tests, most receive approximately one test a year.7, 18 Patients living in higher population areas are more likely to have a test repeated.18

This report examines trends in echocardiography between 2007 and 2011. For these years, we describe trends in echocar-diography services (see Table 1 for service codes) by numbers of services performed, place of service, and population characteristics. We also describe geographic variation in use of echocardiography. We would like to acknowledge the leadership of the DEcIDE Cardiovascular Consortium in establishing the scope and objectives of this report.

Table 1 Echocardiography service category codes

Service categories | BETOS and HCPCS codes | Code definitions
Base services | BETOS code I3C | Echocardiography-Heart
Base services | exclude HCPCS code 93299 | Interrogation device evaluation
Base services | include HCPCS code 93350 | Real-time transthoracic echocardiography with 2D image documentation
Base services | include HCPCS code 93662 | Intracardiac echocardiography during therapeutic or diagnostic intervention
Add-on services | HCPCS code 92978 | Intravascular ultrasound on initial vessel
Add-on services | HCPCS code 92979 | Intravascular ultrasound on additional vessel
Add-on services | HCPCS code 93320 | Complete Doppler echocardiography
Add-on services | HCPCS code 93321 | Follow-up or limited Doppler echocardiography
Add-on services | HCPCS code 93325 | Doppler echocardiography color flow velocity mapping
Add-on services | HCPCS code 93352 | Use of echocardiographic contrast agent during stress echocardiography
Add-on services | HCPCS code 93571 | Intravascular Doppler velocity and/or pressure derived coronary flow reserve measurement during coronary angiography on initial vessel
Add-on services | HCPCS code 93572 | Intravascular Doppler during coronary angiography on additional vessel
Associated services^*^ | HCPCS codes 93016-93016 | Exercise portion of echocardiography stress test
Associated services^*^ | HCPCS codes Q9955-Q9963 | Echocardiography contrast agent
Associated services^*^ | HCPCS codes 76376-76377 | 3D rendering of ultrasound on an independent workstation

* Associated services only included if present on the same day as their assosiated base service.

## METHODS

The analysis was performed using Medicare enrollment data and 100 percent fee-for-service (FFS) Parts A and B institutional/noninstitutional claims data for years 2007 through 2011. The source of the claims and enrollment data was the CMS Chronic Conditions Warehouse (CCW).

We identified Medicare beneficiaries age 65 or older who had Part A and Part B Medicare coverage with no Medicare Advantage (i.e., managed care enrollment) during their period of eligibility and who received echocardiography services during the reference year. Receipt of service was identified by Berenson-Eggers type of service (BETOS) code I3C, excluding Health Care Common Procedure Coding System (HCPCS) code 93299, and including HCPCS codes 93350 and 93662.^19^ Multiple procedures for the same beneficiary in a day were coded as a single event.

We assessed trends in procedures across years and demographic factors, including age and gender (identified in the beneficiary summary file during the year the procedure took place), as well as race/ethnicity, region, and urbanicity as defined below (see Table 2).

Table 2 Distribution of echocardiography services by population characteristics, 2011

Variable | | Beneficiaries eligible for service (#) | Beneficiaries with 1+ service (#) | Beneficiaries with 1+ service (%) | Total services performed (#)
Overall | | 27,573,766 | 5,532,382 | 20.1 | 7,077,554
Age | 65-69 | 7,713,925 | 1,032,162 | 13.4 | 1,314,172
Age | 70-74 | 6,209,355 | 1,165,316 | 18.8 | 1,490,963
Age | 75-79 | 4,942,090 | 1,123,662 | 22.7 | 1,451,375
Age | 80-84 | 4,074,441 | 1,048,791 | 25.7 | 1,354,254
Age | 85+ | 4,633,955 | 1,162,451 | 25.1 | 1,466,790
Race or ethnicity | Non-Hispanic White | 22,979,360 | 4,589,608 | 20.0 | 5,844,857
Race or ethnicity | African American | 2,094,435 | 459,306 | 21.9 | 608,894
Race or ethnicity | Hispanic | 1,464,107 | 299,060 | 20.4 | 390,346
Race or ethnicity | Asian or Pacific Islander | 652,955 | 122,650 | 18.8 | 154,283
Race or ethnicity | American Indian / Alaska Native | 113,320 | 18,635 | 16.4 | 24,228
Race or ethnicity | Other / Unknown | 269,589 | 43,123 | 16.0 | 54,946
Gender | Female | 15,728,969 | 3,048,878 | 19.4 | 3,845,793
Gender | Male | 11,844,797 | 2,483,504 | 21.0 | 3,231,761
Urbanicity | Urban | 24,794,198 | 5,061,675 | 20.4 | 6,469,682
Urbanicity | Rural | 2,700,357 | 465,500 | 17.2 | 601,408
Urbanicity | Unknown | 79,211 | 5,207 | 6.6 | 6,464
Medicare Status | Full dual | 3,054,680 | 761,650 | 23.9 | 1,018,969
Medicare Status | Nondual | 23,146,402 | 4,566,276 | 19.7 | 5,771,201
Medicare Status | Partial dual | 483,067 | 109,052 | 22.6 | 143,341
Medicare Status | QMB | 454,752 | 103,624 | 22.8 | 136,002

QMB = qualified Medicare beneficiary.

### Beneficiary demographic and geographic characteristics

Race/ethnicity: Race and ethnicity were defined using the Research Triangle Institute Race Code, which applies a surname algorithm to assign Hispanic ethnicity.20, 21

Age: The age categories were defined using the age of the beneficiary at the end of each reference year.

Urban/Rural: We used the Core Based Statistical Area (CBSA) of the beneficiary to identify the urban region in which the beneficiary resides. Beneficiaries who do not reside in a CBSA are considered to be rural.22

Dual Status: CMS has an established algorithm for defining the annual dual eligibility status of each beneficiary using the monthly State Reported Dual Eligibility Status Codes.

The algorithm categorizes beneficiaries into four groups: Full Duals had full Medicare and Medicaid coverage (including prescription drugs) during the most recent month of dual eligibility for the reference year; QMB beneficiaries had Medicaid and participated in the Qualified Medicare Beneficiary Program during the most recent month of dual eligibility for the reference year; Other/Partial Duals had Medicaid and participated in the Specified Low-Income Medicare Beneficiary Program during the most recent month of dual eligibility for the reference year, the Qualifying Individual Program, or the Qualified Disabled and Working Individuals Program; and Nonduals had Medicare coverage only for the reference year.23

Costs of echocardiography services were computed as Medicare allowed costs, which include the costs paid by Medicare and the beneficiary contribution, coinsurance, and deductible. Costs were split into several service categories defined below.

### Service categories

Base, Add-on, and Associated Services: Service category codes and definitions are displayed in Table 1.

Physician Specialty: Part B institutional echocardiography services were classified Outpatient Facility specialty services.

For Part B noninstitutional echocardiography services, the specialty of the physician is identified on the service line item of the claim using HCFA specialty code. We classified the specialty as follows: Cardiology = 06; Internal Medicine = 11; General/family practice = 01 or 08; Diag-nostic Radiology = 30; Independent diagnostic testing facility = 47; and other for any other designation. Multiple physician specialties could be included for each echocardiography service.

Place of Service: The place of service is Outpatient and ER for Part B institutional echocardiography services. For Part B noninstitutional echocardiography services, the place of service is identified on the service line item of the claim using HCFA place of service code.

We classified the place of service as follows: Inpatient = 21; Outpatient and ER = 22 or 23; Office and Independent Diagnostic Testing Facility (IDTF) = 11, or if physician specialty = 47; and other for any other designation.24 Only one place of service is included per echocardiography service.

Although we examined data from 2007 to 2011, results from 2011 only are presented in the main body of this report. Results for earlier years appear in the Appendixes.

## RESULTS

From 2007 through 2011, approximately 34 million echocardiography procedures were performed on Medicare beneficiaries. The number of beneficiaries receiving echocardiography procedures was relatively constant between 6.8 million in 2007 and 7 million in 2011 (Figure 1). Of all Medicare beneficiaries, about 20 percent received an echocardiography service in 2011 (Figure 2). This proportion remained fairly constant, increasing only slightly between 2007 and 2011 (from 19.7% in 2007 to 20.1% in 2011).

The proportion of beneficiaries receiving echocardiography services varied with age, increasing between ages 65 and 84 from 13.4 percent to 25.7 percent, and decreasing slightly at age 85 and older to 25.1 percent in 2011 (Figure 3).

In 2011, non-Hispanic White and Hispanic populations both received echocardiography services at a rate of about 20 percent (20.0% and 20.4%, respectively). Among African Americans the rate was slightly higher at about 21.9 percent, and Asians/Pacific Islander and American Indians/Alaska Natives had lower rates at 18.8 percent and 16.4 percent, respectively (Table 2).

Females received echocardiography services at a lower rate than males (19.4% versus 21.0%). Full dual beneficiaries received a higher proportion of services (23.9%) than nonduals (19.7%), partial duals (22.6%), and QMBs (22.8%; Table 2).

The rates of echocardiography services received vary by State. In 2011, New York and New Jersey had the highest proportion of beneficiaries receiving echocardiography at 27.3 percent and 26.5 percent, followed by Florida at 25.2 percent (Figure 4A). Idaho and Alaska had the lowest proportion at 12.7 percent and 13.1 percent. Geographic patterns are largely similar across states for urban and rural areas (Figures 4B-4C). Urban beneficiaries received echocardiography services at a higher rate (20.4%) than rural beneficiaries (17.2%, Table 2).

Figure 4A Eligible beneficiaries receiving echocardiography services, by State, 2011

Map shows that New York, New Jersey, and Florida have the highest percentage (25-30%) of beneficiaries receiving echocardiography services. The South and Northeast have higher rates of echocardiography use than the Western States.

Figure 4B Eligible rural beneficiaries receiving echocardiography services, by State, 2011

*Delaware excluded due to cell size of <11. Values for Hawaii and Rhode Island are not shown due to lack of rural population as coded in this analysis. Full data are available in Appendix L.

Map shows that there is variation in the percentage of eligible rural beneficiaries receiving echocardiography services by state, with the highest percentages in the Northeast and Southeast and lowest percentages in the Western states.

Figure 4C Eligible urban beneficiaries receiving echocardiography services, by State, 2011

Map shows that there is variation in the percentage of eligible urban beneficiaries receiving echocardiography services by state, with the highest percentages in the Northeast and Southeast and lowest percentages in the Western states.

Among Medicare beneficiaries who received echocardiography services in 2011, the average number of echocardiograms per person per year was 1.3 (Table 3). Most beneficiaries who received echocardiography services had one service a year.

Table 3 Echocardiography services among beneficiaries who received at least one echocardiography service by population characteristics, 2011

Variable | | Beneficiaries with 1+ service (#) | Echo services received (#) | Mean services received per beneficiary (#) | Beneficiaries receiving 1 echo | | Beneficiaries receiving 2+ echos
Variable | | Beneficiaries with 1+ service (#) | Echo services received (#) | Mean services received per beneficiary (#) | # | % | # | %
Overall | | 5,532,382 | 7,077,554 | 1.28 | 4,436,663 | 80.2 | 1,095,719 | 19.8
Age | 65-69 | 1,032,162 | 1,314,172 | 1.27 | 839,076 | 81.3 | 193,086 | 18.7
Age | 70-74 | 1,165,316 | 1,490,963 | 1.28 | 939,231 | 80.6 | 226,085 | 19.4
Age | 75-79 | 1,123,662 | 1,451,375 | 1.29 | 894,790 | 79.6 | 228,872 | 20.4
Age | 80-84 | 1,048,791 | 1,354,254 | 1.29 | 830,629 | 79.2 | 218,162 | 20.8
Age | 85+ | 1,162,451 | 1,466,790 | 1.26 | 932,937 | 80.3 | 229,514 | 19.7
Race or ethnicity | Non-Hispanic White | 4,589,608 | 5,844,857 | 1.27 | 3,699,087 | 80.6 | 890,521 | 19.4
Race or ethnicity | African American | 459,306 | 608,894 | 1.33 | 353,982 | 77.1 | 105,324 | 22.9
Race or ethnicity | Hispanic | 299,060 | 390,346 | 1.31 | 234,440 | 78.4 | 64,620 | 21.6
Race or ethnicity | Asian or Pacific Islander | 122,650 | 154,283 | 1.26 | 99,702 | 81.3 | 22,948 | 18.7
Race or ethnicity | American Indian / Alaska Native | 18,635 | 24,228 | 1.30 | 14,575 | 78.2 | 4,060 | 21.8
Race or ethnicity | Other / Unknown | 43,123 | 54,946 | 1.27 | 34,877 | 80.9 | 8,246 | 19.1
Gender | Female | 3,048,878 | 3,845,793 | 1.26 | 2,471,674 | 81.1 | 577,204 | 18.9
Gender | Male | 2,483,504 | 3,231,761 | 1.30 | 1,964,989 | 79.1 | 518,515 | 20.9
Urbanicity | Urban | 5,061,675 | 6,469,682 | 1.28 | 4,063,875 | 80.3 | 997,800 | 19.7
Urbanicity | Rural | 465,500 | 601,408 | 1.29 | 368,486 | 79.2 | 97,014 | 20.8
Urbanicity | Unknown | 5,207 | 6,464 | 1.24 | 4,302 | 82.6 | 905 | 17.4
Medicare Status | Full dual | 760,274 | 1,018,261 | 1.34 | 577,732 | 76.0 | 182,542 | 24.0
Medicare Status | Nondual | 4,559,432 | 5,779,950 | 1.27 | 3,693,621 | 81.0 | 865,811 | 19.0
Medicare Status | Partial dual | 109,052 | 143,341 | 1.31 | 84,817 | 77.8 | 24,235 | 22.2
Medicare Status | QMB | 103,624 | 136,002 | 1.31 | 80,493 | 77.7 | 23,131 | 22.3

QMB = qualified Medicare beneficiary.

In 2011, 80.2 percent received only one service a year, 14.7 percent had two services, 3.4 percent had three services, 1.0 percent had four services, and only 0.7 percent had five or more services a year (Figure 5). This distribution of services was fairly constant between 2007 and 2011. There was a small increase in the percentage of beneficiaries receiving four and five or more services (from 0.9% in 2007 to 1.0% in 2011 for four services, and from 0.6% in 2007 to 0.7% in 2011 for five or more services).

Figure 5 Eligible beneficiaries receiving echocardiography services, by number of services received, 2011

Figure showing the percent of Medicare beneficiaries receiving 1 or more echocardiography services in 2011. 80% of beneficiaries receiving an echocardiography service had only 1 service, 15% had 2, 3% had 3, 1% had 4, and 1% had 5 or more echocardiography services.

Among racial and ethnic groups, African Americans, Hispanics, and American Indians/Alaska Natives were slightly more likely to receive two or more echocardiography services a year than non-Hispanic Whites and Asians/Pacific Islanders in 2011 (Table 3).

Females were more likely to have only one echocardiogram per year than males, with 81.1 percent of females receiving only one service while 79.1 percent of males received one service.

Full duals were more likely to have two or more echocardiography services than nonduals, partial duals, and QMBs (Table 3).

Across the different service settings where echocardiography was performed, the inpatient setting had the highest mean number of services (1.3 per beneficiary per year), followed by outpatient and emergency room (1.1), office and independent diagnostic testing facility (1.1), and all other settings (1.1; Appendix G).

Total allowed health care charges for echocardiography were $1.6 billion in 2011, a decrease from $1.85 billion in 2007 (Figure 6). Of practice specialties that performed echocardiography, cardiology had the highest allowed charges overall. However, the charges within cardiology decreased over time, from $1.14 billion in 2007 to $839 million in 2011 (Figure 6, Appendix H). Allowed charges in other specialties also decreased over time, with the exception of those for outpatient facilities, which increased from $404 million in 2007 to $604 million in 2011 (Figure 6, Appendix H).

Figure 6 Total allowed charges for echocardiography by type of health care provider, 2007-2011

IDTF = Independent Diagnostic Testing Facility.

Figure showing total allowed charges for echocardiography by type of health care provider completing the service from 2007-2011. Total allowed charges were at about $1.8 billion in 2007, decreasing to $1.6 billion in 2011. Cardiology has the highest allowed charges, at about $1.2 billion in 2007 decreasing to about $0.8 billion in 2011. Charges in outpatient facility increased from about $0.4 billion in 2007 to $0.6 billion in 2011.

## DISCUSSION

Echocardiography is a widely used service within the Medicare program. Each year approximately 20 percent of beneficiaries in the fee-for-service (FFS) Medicare program received at least one procedure. Of this group, 20 to 30 percent received more than one echocardiography service.

While a variety of efforts were undertaken in an attempt to control rising costs for cardiac echocardiograms, their success was modest at best. Total allowed charges decreased from 2007 through 2011, while the number of procedures rose slightly and the average number of procedures per beneficiary per year remained essentially unchanged. Findings indicated a very small decrease in the percentage of beneficiaries receiving echo procedures from 2009-2010 (20.4%) to 2011 (20.1%, Appendix K), but among those receiving services, the number of services received generally slightly increased. This suggests that, to date, changes in payments are not reducing use of the procedure.

This analysis identifies two dramatic trends. First, among age groups, the use of echocardiography rose steeply until age 85, when it plateaued. This pattern suggests that use of echocardiography will continue to rise given the aging of the Medicare population.

Second, tremendous geographic variation continues to exist in use of echocardiography. As shown in Figures 4A-4C and Appendices A-F, I, and L, State-to-State variability in echocardiography use was large, and is unlikely to be explained by differences in payment policy alone. Whether measures of health care resources such as cardiologists or echocardiography facilities explain these patterns exceeds the scope of this report. Such questions deserve further exploration.

Further variations were evident among other characteristics, including by urbanicity, reinforcing earlier findings regarding lower rates of use among rural beneficiaries. Variations in use within racial/ethnic groups also exist but appear to be stable over the period 2007-2011. Further work is needed to establish the degree to which these patterns represent intersections in health care access, groupwide differences in health status, or varying propensity for use or recommendation of use in these populations.

Over the study period, the Medicare population increased more quickly in some racial/ethnic subgroups than others. Even if the percentage of Medicare beneficiaries receiving echocardiography services remains stable over time, population increases in these subgroups within Medicare may affect the total number of echocardiography services performed. This implies that efforts to decrease echocardiography use will not just need to be sensitive to overall population trends, but also take into account trends in use in racial/ethnic subgroups within the Medicare population.

This report includes some limitations. First, we only counted one procedure per day. Thus, we may have slightly under-counted the total number of procedures if a significant number of beneficiaries had two or more procedures on the same day. However, these procedures would be captured in total allowed charges.

Second, claims data do not contain information about the indication for the procedure nor of the test result or action that may have been guided by the procedure. Thus, we cannot quantify whether the echocardiography use resulted in important information that was used to direct clinical care.

Third, we present unadjusted numbers only and do not conduct statistical testing of differences in proportions. Because our sample includes the entire Medicare FFS population for all study years, we are able to conduct analyses on the full population of interest rather than a sample. Statistical inference is needed only when evaluating the potential error of the sample, and thus is not necessary in this situation.25 In addition, calculations of standard errors and standard statistical tests commonly incorporate sample size. With the large size of the full Medicare FFS population, it is likely that even small, unimportant trends would be measured as being statistically different.26 Therefore, we chose to omit statistical testing and leave conclusions about the importance of patterns to the reader. In spite of these limitations, we believe that the results of this inquiry provide important insights about the use of echocardiography over time and across geographic and demographic groups.

## CONCLUSION

Echocardiography is a widely used procedure among the Medicare-enrolled population. Each year approximately 20 percent of enrollees in the FFS system receive at least one cardiac echocardiogram. There is sizable geographic variation in use of echocardiography that deserves investigation. Recent changes in reimbursement policy appear to have reduced total allowed charges but have not led to shifts in the percentage of enrollees receiving services nor in the average number of echocardiography services per recipient.

## REFERENCES

1 Minino AM, Murphy SL. (2012). Death in the United States, 2010. Data Brief #99.
2 National Heart, Lung, and Blood Institute, National Institutes of Health. (2011). What is echocardiography?.
3 Medine Plus, National Institutes of Health. (2011). Echocardiogram.
4 Pearlman AS, Ryan T, Picard M, Douglas PS. (2007). Evolving trends in the use of echocardiography: a study of Medicare beneficiaries. J Am Coll Cardiol.
5 Levin DC, Rao VM, Maitino AJ, et al. (2004). Comparative increases in utilization rates of ultrasound examinations among radiologists, cardiologists, and other physicians from 1993 to 2001. J Am Coll Radiol.
6 (2012). Medicare Payment Advisory Commission. A data book: health care spending and the Medicare program.
7 Okrah KM, Vaughan-Sarrazin M, Cram P. (2010). Trends in echocardiography utilization in the Veterans Administration healthcare system. Am Heart J.
8 Levin DC, Rao VM, Parker L, et al. (2011). Bending the curve: the recent marked slowdown in growth of noninvasive diagnostic imaging. Am J Roentgenol.
9 Centers for Medicare & Medicaid Services Medicare Learning Network. (2011). Multiple procedure reduction on the technical component (TC) of certain diagnostic imaging procedures and cap on the TC of imaging procedures. MLN Matters #SE0665 Revised.
10 Wilson JJ. (2006). Deficit Reduction Act of 2005: summary of Medicaid/Medicare/health provisions.
11 (2005). The Deficit Reduction Act of 2005. Public Law 109-171, Sec 5102.
12 American College of Cardiology Foundation Appropriate Use Criteria Task Force, et al. AACF/ASE/AHA/ASNC/HFSA/HRS/SCAI/SCCM/SCCT/SCMR 2011 appropriate use criteria for echocardiography. J Am Coll Cardiol 2011.
13 Chen J, Fazel R, Ross JS, et al. (2011). Do imaging studies performed in physician offices increase downstream utilization?: an empiric analysis of cardiac stress testing with imaging. JACC Cardiovasc Imaging.
14 Levin DC, Rao VM. (2011). The effect of self-referral on utilization of advanced diagnostic imaging. Am J Roentgenol.
15 Parker L, Levin DC, Frangos A, et al. (2010). Geographic variation in the utilization of noninvasive diagnostic imaging: national Medicare data, 1998-2007. Am J Roentenol.
16 Lucas FL, Wennberg DE, Malenka DJ. (1999). Variation in the use of echocardiography. Eff Clin Pract.
17 Okrah K, Vaughan-Sarrazin M, Kaboli P, et al. (2012). Echocardiogram utilization among rural and urban veterans. J Rural Health.
18 Welch GH, Hayes KH, Frost C. (2012). Repeat testing among Medicare beneficiaries. Arch Intern Med.
19 Centers for Medicare & Medicaid Services. Berenson-Eggers type of service (BETOS).
20 Research Data Assistance Center. Research Triangle Institute (RTI) race code.
21 Agency for Healthcare Research and Quality. Creation of new race-ethnicity codes and socio-economic status (SES) indicators for Medicare beneficiaries.
22 United States Census Bureau. Metropolitan and micropolitan statistical areas main.
23 Centers for Medicare & Medicaid Services. Medicare savings programs.
24 Centers for Medicare & Medicaid Services. Place of service codes for professional claims.
25 Feinstein AR. (1985). Clinical epidemiology: the architecture of clinical research.
26 Snedecor GW, Cochran WG. (1989). Statistical methods.

## Acknowledgments

The authors wish to thank the DEcIDE Cardiovascular Consortium for their leadership in establishing the scope and objectives of this report.

This project was funded under Contract No. HH-SA29020100013I from the Agency for Healthcare Research and Quality, U.S. Department of Health and Human Services as part of the Developing Evidence to Inform Decisions about Effectiveness (DEcIDE) program. The authors of this report are responsible for its content. Statements in the report should not be construed as endorsement by the Agency for Healthcare Research and Quality or the U.S. Department of Health and Human Services. This project has been approved by the University of Minnesota Institutional Review Board.

## APPENDICES

Appendix A Echocardiography services performed, by State, 2011

State | Beneficiaries eligible for service (#) | Beneficiaries with 1+ service (#) | Beneficiaries with 1+ service (%) | Total services performed (#)
AK | 52,454 | 6,871 | 13.1 | 8,810
AL | 505,303 | 102,130 | 20.2 | 130,153
AR | 348,532 | 65,101 | 18.7 | 82,614
AZ | 485,314 | 100,220 | 20.7 | 128,095
CA | 2,230,097 | 472,433 | 21.2 | 615,128
CO | 328,316 | 46,929 | 14.3 | 59,061
CT | 363,565 | 71,440 | 19.7 | 89,631
DC | 46,497 | 10,620 | 22.8 | 14,241
DE | 120,051 | 23,398 | 19.5 | 29,053
FL | 1,934,926 | 487,053 | 25.2 | 608,466
GA | 744,747 | 148,972 | 20.0 | 189,598
HI | 89,059 | 12,630 | 14.2 | 15,420
IA | 382,744 | 60,107 | 15.7 | 75,623
ID | 134,040 | 17,070 | 12.7 | 21,248
IL | 1,361,154 | 261,929 | 19.2 | 341,103
IN | 673,268 | 120,072 | 17.8 | 150,990
KS | 318,583 | 56,628 | 17.8 | 74,431
KY | 464,237 | 92,108 | 19.8 | 118,472
LA | 388,219 | 86,344 | 22.2 | 109,073
MA | 649,394 | 117,882 | 18.2 | 149,745
MD | 579,806 | 117,269 | 20.2 | 151,812
ME | 173,816 | 28,390 | 16.3 | 36,634
MI | 986,346 | 230,663 | 23.4 | 299,772
MN | 317,409 | 45,822 | 14.4 | 61,980
MO | 602,310 | 113,844 | 18.9 | 145,413
MS | 337,491 | 64,554 | 19.1 | 83,065
MT | 122,098 | 18,314 | 15.0 | 22,760
NC | 953,706 | 173,071 | 18.2 | 219,443
ND | 82,523 | 11,952 | 14.5 | 14,542
NE | 209,370 | 38,441 | 18.4 | 49,292
NH | 167,368 | 28,402 | 17.0 | 36,768
NJ | 932,941 | 246,913 | 26.5 | 309,890
NM | 173,533 | 25,782 | 14.8 | 32,352
NV | 193,673 | 43,310 | 22.4 | 55,913
NY | 1,524,357 | 416,217 | 27.3 | 535,682
OH | 956,047 | 178,781 | 18.7 | 228,927
OK | 408,979 | 74,979 | 18.3 | 93,632
OR | 288,370 | 37,910 | 13.2 | 48,112
PA | 1,085,910 | 227,141 | 20.9 | 291,808
PR | 70,153 | 13,539 | 19.3 | 15,767
RI | 79,821 | 15,701 | 19.7 | 19,889
SC | 525,538 | 100,428 | 19.1 | 126,748
SD | 104,675 | 14,612 | 14.0 | 18,314
TN | 614,245 | 110,196 | 17.9 | 139,972
TX | 1,891,046 | 401,334 | 21.2 | 522,605
UT | 144,512 | 20,959 | 14.5 | 28,152
VA | 795,195 | 136,780 | 17.2 | 172,387
VI | 13,789 | 1,444 | 10.5 | 1,772
VT | 85,025 | 11,612 | 13.7 | 14,483
WA | 575,926 | 83,638 | 14.5 | 103,196
WI | 513,443 | 79,873 | 15.6 | 104,937
WV | 214,570 | 39,960 | 18.6 | 52,285
WY | 65,318 | 8,747 | 13.4 | 11,338

Appendix B Echocardiography services performed, by population characteristics, 2010

Variable | | Beneficiaries eligible for service (#) | Beneficiaries with 1+ service (#) | Beneficiaries with 1+ service (%) | Total services performed (#)
Overall | | 27,073,765 | 5,529,233 | 20.4 | 7,054,577
Age | 65-69 | 7,333,868 | 1,021,115 | 13.9 | 1,296,139
Age | 70-74 | 6,079,102 | 1,158,197 | 19.1 | 1,478,879
Age | 75-79 | 4,943,934 | 1,131,466 | 22.9 | 1,458,545
Age | 80-84 | 4,136,721 | 1,070,602 | 25.9 | 1,378,020
Age | 85+ | 4,580,140 | 1,147,853 | 25.1 | 1,442,994
Race or ethnicity | Non-Hispanic White | 22,651,929 | 4,600,895 | 20.3 | 5,840,744
Race or ethnicity | African American | 2,042,391 | 452,770 | 22.2 | 600,533
Race or ethnicity | Hispanic | 1,419,366 | 298,691 | 21.0 | 389,721
Race or ethnicity | Asian or Pacific Islander | 626,647 | 119,950 | 19.1 | 150,601
Race or ethnicity | American Indian / Alaska Native | 109,991 | 18,217 | 16.6 | 23,607
Race or ethnicity | Other / Unknown | 223,441 | 38,710 | 17.3 | 49,371
Gender | Female | 15,522,435 | 3,054,957 | 19.7 | 3,844,645
Gender | Male | 11,551,330 | 2,474,276 | 21.4 | 3,209,932
Urbanicity | Urban | 24,320,726 | 5,059,361 | 20.8 | 6,448,865
Urbanicity | Rural | 2,672,089 | 464,365 | 17.4 | 598,944
Urbanicity | Unknown | 80,950 | 5,507 | 6.8 | 6,768
Medicare Status | Full dual | 3,054,680 | 761,650 | 24.9 | 1,018,969
Medicare Status | Nondual | 23,146,402 | 4,566,276 | 19.7 | 5,771,201
Medicare Status | Partial dual | 452,620 | 103,827 | 22.9 | 136,079
Medicare Status | QMB | 420,063 | 97,480 | 23.2 | 128,328
State | AK | 49,853 | 6,526 | 13.1 | 8,399
State | AL | 487,888 | 99,518 | 20.4 | 126,719
State | AR | 342,630 | 63,837 | 18.6 | 80,522
State | AZ | 464,529 | 97,653 | 21.0 | 125,374
State | CA | 2,167,494 | 466,229 | 21.5 | 606,022
State | CO | 312,252 | 46,931 | 15.0 | 59,313
State | CT | 363,144 | 73,098 | 20.1 | 91,811
State | DC | 45,700 | 10,397 | 22.7 | 13,883
State | DE | 116,646 | 22,295 | 19.1 | 27,502
State | FL | 1,919,716 | 497,403 | 25.9 | 619,044
State | GA | 723,319 | 146,756 | 20.3 | 186,326
State | HI | 87,956 | 13,369 | 15.2 | 16,524
State | IA | 375,488 | 59,928 | 16.0 | 74,734
State | ID | 127,868 | 16,857 | 13.2 | 21,024
State | IL | 1,323,692 | 258,756 | 19.6 | 336,407
State | IN | 667,356 | 122,082 | 18.3 | 153,574
State | KS | 314,554 | 57,432 | 18.3 | 75,568
State | KY | 455,976 | 90,770 | 19.9 | 116,332
State | LA | 378,972 | 85,536 | 22.6 | 108,069
State | MA | 618,380 | 113,683 | 18.4 | 144,628
State | MD | 564,176 | 113,376 | 20.1 | 145,459
State | ME | 171,849 | 28,236 | 16.4 | 36,594
State | MI | 1,088,269 | 256,270 | 23.6 | 329,698
State | MN | 330,835 | 48,512 | 14.7 | 64,722
State | MO | 610,732 | 111,949 | 18.3 | 143,687
State | MS | 329,496 | 63,834 | 19.4 | 81,669
State | MT | 113,638 | 17,799 | 15.7 | 22,154
State | NC | 953,706 | 173,071 | 18.2 | 219,443
State | ND | 83,978 | 11,627 | 13.9 | 14,970
State | NE | 204,135 | 38,506 | 18.9 | 49,758
State | NH | 159,323 | 27,617 | 17.3 | 35,907
State | NJ | 918,591 | 250,064 | 27.2 | 313,124
State | NM | 170,756 | 25,702 | 15.1 | 32,116
State | NV | 185,633 | 43,399 | 23.4 | 55,570
State | NY | 1,514,814 | 419,247 | 27.7 | 538,582
State | OH | 946,802 | 180,518 | 19.1 | 230,363
State | OK | 399,603 | 73,823 | 18.5 | 91,659
State | OR | 270,336 | 35,861 | 13.3 | 45,532
State | PA | 1,063,986 | 226,764 | 21.3 | 290,473
State | PR | 76,515 | 14,602 | 19.1 | 16,924
State | RI | 78,199 | 15,534 | 19.9 | 19,757
State | SC | 505,238 | 99,133 | 19.6 | 124,629
State | SD | 105,701 | 15,118 | 14.3 | 19,070
State | TN | 599,359 | 108,749 | 18.1 | 136,683
State | TX | 1,891,046 | 401,334 | 21.2 | 522,605
State | UT | 140,795 | 20,930 | 14.9 | 27,688
State | VA | 764,850 | 130,056 | 17.0 | 162,886
State | VI | 13,107 | 1,345 | 10.3 | 1,654
State | VT | 83,611 | 11,928 | 14.3 | 14,879
State | WA | 557,857 | 83,184 | 14.9 | 102,833
State | WI | 508,020 | 80,287 | 15.8 | 105,292
State | WV | 209,864 | 38,982 | 18.6 | 50,830
State | WY | 62,865 | 8,289 | 13.2 | 10,664

Appendix C Echocardiography services performed, by population characteristics, 2009

Variable | | Beneficiaries eligible for service (#) | Beneficiaries with 1+ service (#) | Beneficiaries with 1+ service (%) | Total services performed (#)
Overall | | 26,828,437 | 5,471,903 | 20.4 | 6,951,249
Age | 65-69 | 7,178,201 | 1,004,211 | 14.0 | 1,268,115
Age | 70-74 | 6,024,406 | 1,143,243 | 19.0 | 1,449,991
Age | 75-79 | 4,981,063 | 1,137,092 | 22.8 | 1,462,245
Age | 80-84 | 4,157,162 | 1,068,915 | 25.7 | 1,370,300
Age | 85+ | 4,487,605 | 1,118,442 | 24.9 | 1,400,598
Race or ethnicity | Non-Hispanic White | 22,550,084 | 4,571,325 | 20.3 | 5,777,095
Race or ethnicity | African American | 1,992,097 | 440,190 | 22.1 | 582,155
Race or ethnicity | Hispanic | 1,378,603 | 291,778 | 21.2 | 379,053
Race or ethnicity | Asian or Pacific Islander | 600,124 | 115,323 | 19.2 | 144,563
Race or ethnicity | American Indian / Alaska Native | 106,644 | 17,448 | 16.4 | 22,710
Race or ethnicity | Other / Unknown | 200,885 | 35,839 | 17.8 | 45,673
Gender | Female | 15,443,039 | 3,042,810 | 19.7 | 3,814,599
Gender | Male | 11,385,398 | 2,429,093 | 21.3 | 3,136,650
Urbanicity | Urban | 24,088,521 | 5,007,741 | 20.8 | 6,357,597
Urbanicity | Rural | 2,662,179 | 458,741 | 17.2 | 586,857
Urbanicity | Unknown | 77,737 | 5,421 | 4.0 | 6,795
Medicare Status | Full dual | 3,033,006 | 755,642 | 24.9 | 1,009,576
Medicare Status | Nondual | 22,977,963 | 4,526,258 | 19.7 | 5,693,447
Medicare Status | Partial dual | 430,729 | 99,546 | 23.1 | 129,829
Medicare Status | QMB | 386,739 | 90,457 | 23.4 | 118,397
State | AK | 47,552 | 5,989 | 12.6 | 7,622
State | AL | 471,448 | 95,519 | 20.3 | 120,332
State | AR | 340,434 | 62,951 | 18.5 | 79,515
State | AZ | 443,653 | 93,684 | 21.1 | 119,838
State | CA | 2,134,931 | 457,158 | 21.4 | 592,631
State | CO | 302,594 | 45,268 | 15.0 | 57,254
State | CT | 365,058 | 74,103 | 20.3 | 92,838
State | DC | 44,777 | 9,996 | 22.3 | 13,260
State | DE | 111,970 | 21,031 | 18.8 | 25,781
State | FL | 1,913,328 | 497,380 | 26.0 | 616,112
State | GA | 768,685 | 152,335 | 19.8 | 192,294
State | HI | 87,646 | 13,544 | 15.5 | 16,499
State | IA | 374,055 | 59,389 | 15.9 | 73,808
State | ID | 126,279 | 16,472 | 13.0 | 20,487
State | IL | 1,302,362 | 252,199 | 19.4 | 327,114
State | IN | 666,520 | 123,904 | 18.6 | 155,653
State | KS | 312,165 | 56,409 | 18.1 | 73,900
State | KY | 454,463 | 91,892 | 20.2 | 117,802
State | LA | 378,742 | 85,411 | 22.6 | 107,937
State | MA | 609,893 | 113,376 | 18.6 | 145,118
State | MD | 555,026 | 111,715 | 20.1 | 143,422
State | ME | 173,394 | 28,530 | 16.4 | 36,755
State | MI | 926,814 | 222,191 | 24.0 | 282,908
State | MN | 360,443 | 51,786 | 14.4 | 68,992
State | MO | 602,844 | 114,274 | 19.0 | 146,049
State | MS | 323,191 | 62,547 | 19.4 | 79,906
State | MT | 112,337 | 17,302 | 15.4 | 21,423
State | NC | 928,373 | 167,157 | 18.0 | 211,344
State | ND | 84,070 | 11,408 | 13.6 | 14,065
State | NE | 202,579 | 37,447 | 18.5 | 48,421
State | NH | 157,327 | 27,540 | 17.5 | 35,707
State | NJ | 907,255 | 251,077 | 27.7 | 313,261
State | NM | 167,207 | 24,539 | 14.7 | 31,645
State | NV | 178,341 | 41,680 | 23.4 | 53,422
State | NY | 1,526,148 | 419,633 | 27.5 | 537,745
State | OH | 1,059,145 | 202,468 | 19.1 | 255,598
State | OK | 396,686 | 74,219 | 18.7 | 92,568
State | OR | 262,711 | 34,289 | 13.1 | 42,391
State | PA | 1,051,567 | 225,492 | 21.4 | 287,256
State | PR | 82,469 | 16,042 | 19.5 | 18,737
State | RI | 75,830 | 15,369 | 20.3 | 19,286
State | SC | 494,877 | 97,182 | 19.6 | 122,101
State | SD | 105,714 | 15,614 | 14.8 | 19,613
State | TN | 596,261 | 108,376 | 18.2 | 135,515
State | TX | 1,863,060 | 394,553 | 21.2 | 507,485
State | UT | 141,487 | 20,638 | 14.6 | 27,152
State | VA | 751,258 | 125,864 | 16.8 | 156,617
State | VI | 12,403 | 1,289 | 10.4 | 1,601
State | VT | 81,818 | 11,807 | 14.4 | 14,712
State | WA | 548,882 | 81,978 | 14.9 | 101,157
State | WI | 516,329 | 81,376 | 15.8 | 106,196
State | WV | 205,998 | 38,045 | 18.5 | 49,222
State | WY | 62,263 | 7,952 | 12.8 | 10,068

Appendix D Echocardiography services performed, by population characteristics, 2008

Variable | | Beneficiaries eligible for service (#) | Beneficiaries with 1+ service (#) | Beneficiaries with 1+ service (%) | Total services performed (#)
Overall | | 27,017,354 | 5,455,367 | 20.2 | 6,918,949
Age | 65-69 | 7,113,764 | 981,425 | 13.8 | 1,234,117
Age | 70-74 | 6,078,691 | 1,134,214 | 18.7 | 1,436,822
Age | 75-79 | 5,104,045 | 1,152,390 | 22.6 | 1,478,246
Age | 80-84 | 4,274,722 | 1,085,782 | 25.4 | 1,390,695
Age | 85+ | 4,446,132 | 1,101,556 | 24.8 | 1,379,069
Race or ethnicity | Non-Hispanic White | 22,819,154 | 4,586,260 | 20.1 | 5,791,497
Race or ethnicity | African American | 1,969,333 | 425,943 | 21.6 | 560,100
Race or ethnicity | Hispanic | 1,355,144 | 282,400 | 20.8 | 364,907
Race or ethnicity | Asian or Pacific Islander | 580,375 | 111,003 | 19.1 | 138,727
Race or ethnicity | American Indian / Alaska Native | 104,707 | 16,461 | 15.7 | 21,384
Race or ethnicity | Other / Unknown | 188,641 | 33,300 | 17.7 | 42,334
Gender | Female | 15,594,544 | 3,042,059 | 19.5 | 3,807,416
Gender | Male | 11,422,810 | 2,413,308 | 21.1 | 3,111,533
Urbanicity | Urban | 24,255,594 | 4,994,523 | 20.6 | 6,329,588
Urbanicity | Rural | 2,685,046 | 455,466 | 17.0 | 582,748
Urbanicity | Unknown | 76,714 | 5,378 | 7.0 | 6,613
Medicare Status | Full dual | 3,017,506 | 739,728 | 24.5 | 982,558
Medicare Status | Nondual | 23,210,226 | 4,535,201 | 19.5 | 5,701,268
Medicare Status | Partial dual | 407,076 | 93,060 | 22.9 | 121,320
Medicare Status | QMB | 382,546 | 87,378 | 22.8 | 113,803
State | AK | 45,813 | 5,689 | 12.4 | 7,341
State | AL | 484,321 | 97,370 | 20.1 | 122,041
State | AR | 340,500 | 61,444 | 18.0 | 78,125
State | AZ | 435,937 | 91,502 | 21.0 | 117,436
State | CA | 2,109,297 | 446,097 | 21.1 | 573,609
State | CO | 299,036 | 44,354 | 14.8 | 55,985
State | CT | 374,748 | 75,052 | 20.0 | 94,401
State | DC | 44,509 | 9,881 | 22.2 | 13,139
State | DE | 110,317 | 21,456 | 19.4 | 26,935
State | FL | 1,929,741 | 495,383 | 25.7 | 612,071
State | GA | 764,735 | 148,681 | 19.4 | 188,274
State | HI | 90,376 | 13,795 | 15.3 | 16,856
State | IA | 377,774 | 60,487 | 16.0 | 75,412
State | ID | 129,393 | 16,363 | 12.6 | 20,181
State | IL | 1,300,249 | 249,542 | 19.2 | 322,490
State | IN | 679,191 | 126,307 | 18.6 | 159,333
State | KS | 316,121 | 57,208 | 18.1 | 74,676
State | KY | 456,858 | 92,183 | 20.2 | 118,092
State | LA | 384,869 | 85,360 | 22.2 | 107,033
State | MA | 610,815 | 113,752 | 18.6 | 145,461
State | MD | 549,284 | 111,085 | 20.2 | 141,767
State | ME | 182,982 | 29,710 | 16.2 | 38,288
State | MI | 965,151 | 229,794 | 23.8 | 290,999
State | MN | 376,639 | 53,591 | 14.2 | 71,817
State | MO | 609,693 | 114,341 | 18.8 | 147,171
State | MS | 321,976 | 59,808 | 18.6 | 75,990
State | MT | 114,065 | 17,911 | 15.7 | 22,181
State | NC | 917,829 | 161,933 | 17.6 | 204,706
State | ND | 84,334 | 11,424 | 13.5 | 13,998
State | NE | 203,102 | 37,688 | 18.6 | 49,094
State | NH | 157,744 | 27,340 | 17.3 | 35,410
State | NJ | 920,205 | 254,410 | 27.6 | 318,980
State | NM | 167,367 | 24,185 | 14.5 | 31,009
State | NV | 174,039 | 40,677 | 23.4 | 52,043
State | NY | 1,549,308 | 420,843 | 27.2 | 536,338
State | OH | 1,075,199 | 206,469 | 19.2 | 260,930
State | OK | 397,580 | 71,975 | 18.1 | 89,790
State | OR | 263,907 | 34,006 | 12.9 | 41,875
State | PA | 1,086,940 | 231,482 | 21.3 | 295,185
State | PR | 96,604 | 18,052 | 18.7 | 20,573
State | RI | 75,603 | 15,341 | 20.3 | 19,393
State | SC | 488,180 | 95,185 | 19.5 | 119,083
State | SD | 101,800 | 13,915 | 13.7 | 17,435
State | TN | 602,933 | 107,016 | 17.7 | 134,563
State | TX | 1,850,884 | 384,808 | 20.8 | 493,541
State | UT | 147,612 | 20,970 | 14.2 | 27,453
State | VA | 749,788 | 125,046 | 16.7 | 155,351
State | VI | 11,741 | 1,086 | 9.2 | 1,325
State | VT | 81,002 | 11,814 | 14.6 | 15,042
State | WA | 549,712 | 79,570 | 14.5 | 97,462
State | WI | 532,790 | 83,238 | 15.6 | 108,674
State | WV | 208,564 | 38,377 | 18.4 | 49,539
State | WY | 61,361 | 7,854 | 12.8 | 9,992

Appendix E Echocardiography services performed, by population characteristics, 2007

Variable | | Beneficiaries eligible for service (#) | Beneficiaries with 1+ service (#) | Beneficiaries with 1+ service (%) | Total services performed (#)
Overall | | 27,461,960 | 5,400,626 | 19.7 | 6,816,517
Age | 65-69 | 7,129,449 | 961,295 | 13.5 | 1,202,741
Age | 70-74 | 6,120,033 | 1,114,190 | 18.2 | 1,405,319
Age | 75-79 | 5,358,238 | 1,179,322 | 22.0 | 1,505,529
Age | 80-84 | 4,409,005 | 1,085,147 | 24.6 | 1,382,968
Age | 85+ | 4,445,235 | 1,060,672 | 23.9 | 1,319,960
Race or ethnicity | Non-Hispanic White | 23,256,128 | 4,547,054 | 19.6 | 5,714,224
Race or ethnicity | African American | 2,016,748 | 424,370 | 21.0 | 554,397
Race or ethnicity | Hispanic | 1,347,634 | 278,017 | 20.6 | 358,498
Race or ethnicity | Asian or Pacific Islander | 558,620 | 104,375 | 18.7 | 129,831
Race or ethnicity | American Indian / Alaska Native | 103,254 | 15,788 | 15.3 | 20,484
Race or ethnicity | Other / Unknown | 179,576 | 31,022 | 17.3 | 39,083
Gender | Female | 15,910,097 | 3,025,762 | 19.0 | 3,770,207
Gender | Male | 11,551,863 | 2,374,864 | 20.6 | 3,046,310
Urbanicity | Urban | 24,659,627 | 4,944,213 | 20.0 | 6,234,124
Urbanicity | Rural | 2,726,689 | 451,234 | 16.5 | 575,969
Urbanicity | Unknown | 75,644 | 5,179 | 6.8 | 6,424
Medicare Status | Full dual | 3,081,855 | 736,700 | 23.9 | 973,092
Medicare Status | Nondual | 23,584,588 | 4,486,961 | 19.0 | 5,613,769
Medicare Status | Partial dual | 418,234 | 92,812 | 22.2 | 120,180
Medicare Status | QMB | 377,283 | 84,153 | 22.3 | 109,476
State | AK | 43,802 | 5,448 | 12.4 | 6,966
State | AL | 503,406 | 97,105 | 19.3 | 120,956
State | AR | 339,253 | 58,811 | 17.3 | 74,488
State | AZ | 430,828 | 86,214 | 20.0 | 111,063
State | CA | 2,081,916 | 427,703 | 20.5 | 543,307
State | CO | 295,162 | 42,825 | 14.5 | 54,231
State | CT | 389,222 | 76,187 | 19.6 | 95,476
State | DC | 45,797 | 9,836 | 21.5 | 12,894
State | DE | 109,108 | 21,090 | 19.3 | 26,090
State | FL | 1,948,673 | 490,391 | 25.2 | 604,845
State | GA | 755,356 | 141,412 | 18.7 | 179,090
State | HI | 90,643 | 13,087 | 14.4 | 15,792
State | IA | 376,500 | 58,177 | 15.5 | 72,568
State | ID | 132,521 | 16,121 | 12.2 | 19,568
State | IL | 1,297,879 | 242,404 | 18.7 | 311,207
State | IN | 691,325 | 124,940 | 18.1 | 156,000
State | KS | 319,567 | 56,256 | 17.6 | 73,617
State | KY | 461,926 | 90,246 | 19.5 | 115,599
State | LA | 395,708 | 85,569 | 21.6 | 107,415
State | MA | 614,508 | 112,194 | 18.3 | 142,916
State | MD | 546,051 | 106,285 | 19.5 | 135,753
State | ME | 186,590 | 29,678 | 15.9 | 38,089
State | MI | 1,043,116 | 244,036 | 23.4 | 307,874
State | MN | 397,599 | 54,975 | 13.8 | 72,393
State | MO | 616,147 | 112,555 | 18.3 | 143,971
State | MS | 319,540 | 58,257 | 18.2 | 73,375
State | MT | 115,605 | 17,825 | 15.4 | 22,019
State | NC | 916,899 | 160,195 | 17.5 | 202,280
State | ND | 84,489 | 11,318 | 13.4 | 14,028
State | NE | 205,534 | 36,575 | 17.8 | 47,522
State | NH | 157,630 | 27,099 | 17.2 | 34,815
State | NJ | 924,872 | 248,979 | 26.9 | 312,005
State | NM | 166,549 | 23,382 | 14.0 | 29,096
State | NV | 169,724 | 38,607 | 22.7 | 48,613
State | NY | 1,600,289 | 419,566 | 26.2 | 530,439
State | OH | 1,196,953 | 227,793 | 19.0 | 287,927
State | OK | 399,320 | 70,688 | 17.7 | 87,985
State | OR | 262,400 | 33,195 | 12.7 | 40,480
State | PA | 1,167,641 | 242,553 | 20.8 | 307,327
State | PR | 103,088 | 19,044 | 18.5 | 21,539
State | RI | 76,392 | 15,148 | 19.8 | 19,085
State | SC | 483,288 | 90,381 | 18.7 | 111,647
State | SD | 103,487 | 13,922 | 13.5 | 17,425
State | TN | 609,791 | 104,834 | 17.2 | 131,601
State | TX | 1,845,286 | 369,484 | 20.0 | 472,776
State | UT | 155,923 | 22,049 | 14.1 | 28,565
State | VA | 752,968 | 121,855 | 16.2 | 150,892
State | VI | 11,094 | 1,027 | 9.3 | 1,220
State | VT | 80,686 | 11,260 | 14.0 | 14,242
State | WA | 550,387 | 78,285 | 14.2 | 95,114
State | WI | 559,100 | 85,440 | 15.3 | 110,939
State | WV | 213,386 | 38,248 | 17.9 | 48,735
State | WY | 60,624 | 7,545 | 12.4 | 9,539

Appendix F Number of annual echocardiography services among beneficiaries with at least one echocardiography service, by State, 2011

State | Beneficiaries (#) | Echo services received (#) | Mean services received per beneficiary (#) | Beneficiaries receiving 1 echo | | Beneficiaries receiving 2+ echos
State | Beneficiaries (#) | Echo services received (#) | Mean services received per beneficiary (#) | (#) | (%) | (#) | (%)
AK | 6,871 | 8,810 | 1.28 | 5,558 | 80.9 | 1,313 | 19.1
AL | 102,130 | 130,153 | 1.27 | 81,515 | 79.8 | 20,615 | 20.2
AR | 65,101 | 82,614 | 1.27 | 52,187 | 80.2 | 12,914 | 19.8
AZ | 100,220 | 128,095 | 1.28 | 80,635 | 80.5 | 19,585 | 19.5
CA | 472,433 | 615,128 | 1.30 | 372,321 | 78.8 | 100,112 | 21.2
CO | 46,929 | 59,061 | 1.26 | 38,218 | 81.4 | 8,711 | 18.6
CT | 71,440 | 89,631 | 1.25 | 58,570 | 82.0 | 12,870 | 18.0
DC | 10,620 | 14,241 | 1.34 | 8,081 | 76.1 | 2,539 | 23.9
DE | 23,398 | 29,053 | 1.24 | 19,342 | 82.7 | 4,056 | 17.3
FL | 487,053 | 608,466 | 1.25 | 398,576 | 81.8 | 88,477 | 18.2
GA | 148,972 | 189,598 | 1.27 | 119,862 | 80.5 | 29,110 | 19.5
HI | 12,630 | 15,420 | 1.22 | 10,522 | 83.3 | 2,108 | 16.7
IA | 60,107 | 75,623 | 1.26 | 49,149 | 81.8 | 10,958 | 18.2
ID | 17,070 | 21,248 | 1.24 | 14,129 | 82.8 | 2,941 | 17.2
IL | 261,929 | 341,103 | 1.30 | 206,820 | 79.0 | 55,109 | 21.0
IN | 120,072 | 150,990 | 1.26 | 97,688 | 81.4 | 22,384 | 18.6
KS | 56,628 | 74,431 | 1.31 | 43,698 | 77.2 | 12,930 | 22.8
KY | 92,108 | 118,472 | 1.29 | 73,179 | 79.4 | 18,929 | 20.6
LA | 86,344 | 109,073 | 1.26 | 70,108 | 81.2 | 16,236 | 18.8
MA | 117,882 | 149,745 | 1.27 | 95,743 | 81.2 | 22,139 | 18.8
MD | 117,269 | 151,812 | 1.29 | 93,635 | 79.8 | 23,634 | 20.2
ME | 28,390 | 36,634 | 1.29 | 22,780 | 80.2 | 5,610 | 19.8
MI | 230,663 | 299,772 | 1.30 | 181,246 | 78.6 | 49,417 | 21.4
MN | 45,822 | 61,980 | 1.35 | 35,094 | 76.6 | 10,728 | 23.4
MO | 111,949 | 143,687 | 1.28 | 89,286 | 79.8 | 22,663 | 20.2
MS | 64,554 | 83,065 | 1.29 | 51,041 | 79.1 | 13,513 | 20.9
MT | 18,314 | 22,760 | 1.24 | 15,167 | 82.8 | 3,147 | 17.2
NC | 177,345 | 225,084 | 1.27 | 143,150 | 80.7 | 34,195 | 19.3
ND | 11,952 | 14,542 | 1.22 | 10,086 | 84.4 | 1,866 | 15.6
NE | 38,441 | 49,292 | 1.28 | 30,877 | 80.3 | 7,564 | 19.7
NH | 28,402 | 36,768 | 1.29 | 22,732 | 80.0 | 5,670 | 20.0
NJ | 246,913 | 309,890 | 1.26 | 202,576 | 82.0 | 44,337 | 18.0
NM | 25,782 | 32,352 | 1.25 | 21,050 | 81.6 | 4,732 | 18.4
NV | 43,310 | 55,913 | 1.29 | 34,725 | 80.2 | 8,585 | 19.8
NY | 416,217 | 535,682 | 1.29 | 332,898 | 80.0 | 83,319 | 20.0
OH | 178,781 | 228,927 | 1.28 | 143,000 | 80.0 | 35,781 | 20.0
OK | 74,979 | 93,632 | 1.25 | 61,298 | 81.8 | 13,681 | 18.2
OR | 37,910 | 48,112 | 1.27 | 30,694 | 81.0 | 7,216 | 19.0
PA | 227,141 | 291,808 | 1.28 | 182,041 | 80.1 | 45,100 | 19.9
PR | 13,539 | 15,767 | 1.16 | 11,806 | 87.2 | 1,733 | 12.8
RI | 15,701 | 19,889 | 1.27 | 12,638 | 80.5 | 3,063 | 19.5
SC | 100,428 | 126,748 | 1.26 | 81,155 | 80.8 | 19,273 | 19.2
SD | 14,612 | 18,314 | 1.25 | 12,030 | 82.3 | 2,582 | 17.7
TN | 110,196 | 139,972 | 1.27 | 88,483 | 80.3 | 21,713 | 19.7
TX | 408,363 | 532,606 | 1.30 | 320,581 | 78.5 | 87,782 | 21.5
UT | 20,959 | 28,152 | 1.34 | 16,375 | 78.1 | 4,584 | 21.9
VA | 136,780 | 172,387 | 1.26 | 111,470 | 81.5 | 25,310 | 18.5
VI | 1,444 | 1,772 | 1.23 | 1,201 | 83.2 | 243 | 16.8
VT | 11,612 | 14,483 | 1.25 | 9,551 | 82.3 | 2,061 | 17.8
WA | 83,638 | 103,196 | 1.23 | 69,520 | 83.1 | 14,118 | 16.9
WI | 79,873 | 104,937 | 1.31 | 62,306 | 78.0 | 17,567 | 22.0
WV | 39,960 | 52,285 | 1.31 | 31,289 | 78.3 | 8,671 | 21.7
WY | 8,747 | 11,338 | 1.30 | 6,940 | 79.3 | 1,807 | 20.7

Appendix G Echocardiography services performed, by site and type of service, 2007-2011

Variable | | All Echocardiography Services | | | Base Services | | | Add-on Services | | | Associated Services
Variable | | Services received (#) | Beneficiaries with 1+ services (#) | Mean services received per beneficiary (#) | Services received (#) | Beneficiaries with 1+ services (#) | Mean services received per beneficiary (#) | Services received (#) | Beneficiaries with 1+ services (#) | Mean services received per beneficiary (#) | Services received (#) | Beneficiaries with 1+ services (#) | Mean services received per beneficiary (#)
Total | 2011 | 7,077,554 | 5,532,382 | 1.28 | 7,019,351 | 5,514,853 | 1.27 | 516,041 | 462,081 | 1.12 | 198,967 | 192,669 | 1.03
Total | 2010 | 7,054,577 | 5,529,233 | 1.28 | 6,997,267 | 5,511,090 | 1.27 | 523,349 | 471,284 | 1.11 | 190,377 | 184,290 | 1.03
Total | 2009 | 6,951,249 | 5,471,903 | 1.27 | 6,898,789 | 5,455,124 | 1.26 | 593,684 | 539,884 | 1.10 | 179,913 | 174,510 | 1.03
Total | 2008 | 6,918,949 | 5,455,367 | 1.27 | 6,862,597 | 5,436,820 | 1.26 | 6,599,687 | 5,297,553 | 1.25 | 169,065 | 164,178 | 1.03
Total | 2007 | 6,816,517 | 5,400,626 | 1.26 | 6,762,239 | 5,381,879 | 1.26 | 6,483,873 | 5,230,268 | 1.24 | 176,065 | 171,260 | 1.03
Total | Total | 34,818,846 | 27,389,511 | 1.27 | 34,540,243 | 27,299,766 | 1.27 | 14,716,634 | 12,001,070 | 1.23 | 914,387 | 886,907 | 1.03
Inpatient | 2011 | 2,444,146 | 1,936,816 | 1.26 | 2,417,293 | 1,923,691 | 1.26 | 188,118 | 167,544 | 1.12 | 25,075 | 24,678 | 1.02
Inpatient | 2010 | 2,442,218 | 1,937,771 | 1.26 | 2,414,389 | 1,923,328 | 1.26 | 188,443 | 168,832 | 1.12 | 27,589 | 27,234 | 1.01
Inpatient | 2009 | 2,428,626 | 1,926,228 | 1.26 | 2,400,794 | 1,911,314 | 1.26 | 196,717 | 177,241 | 1.11 | 28,568 | 28,187 | 1.01
Inpatient | 2008 | 2,494,105 | 1,975,441 | 1.26 | 2,462,507 | 1,958,705 | 1.26 | 2,382,184 | 1,924,379 | 1.24 | 31,186 | 30,749 | 1.01
Inpatient | 2007 | 2,473,342 | 1,964,976 | 1.26 | 2,441,742 | 1,947,717 | 1.25 | 2,357,959 | 1,910,967 | 1.23 | 34,249 | 33,871 | 1.01
Inpatient | Total | 12,282,437 | 9,741,232 | 1.26 | 12,136,725 | 9,664,755 | 1.26 | 5,313,421 | 4,348,963 | 1.22 | 146,667 | 144,719 | 1.01
Outpatient and ER | 2011 | 1,513,258 | 1,329,610 | 1.14 | 1,482,362 | 1,305,942 | 1.14 | 182,347 | 170,954 | 1.07 | 132,614 | 129,385 | 1.02
Outpatient and ER | 2010 | 1,278,120 | 1,130,033 | 1.13 | 1,249,504 | 1,107,313 | 1.13 | 171,064 | 161,097 | 1.06 | 119,257 | 116,535 | 1.02
Outpatient and ER | 2009 | 1,128,888 | 1,007,489 | 1.12 | 1,105,360 | 988,373 | 1.12 | 221,024 | 210,944 | 1.05 | 105,914 | 103,774 | 1.02
Outpatient and ER | 2008 | 1,070,251 | 957,812 | 1.12 | 1,050,684 | 942,214 | 1.12 | 989,914 | 894,376 | 1.11 | 103,898 | 101,748 | 1.02
Outpatient and ER | 2007 | 1,065,625 | 956,215 | 1.11 | 1,049,649 | 943,834 | 1.11 | 980,927 | 888,446 | 1.10 | 108,842 | 106,522 | 1.02
Outpatient and ER | Total | 6,056,142 | 5,381,159 | 1.13 | 5,937,559 | 5,287,676 | 1.12 | 2,545,276 | 2,325,817 | 1.09 | 570,525 | 557,964 | 1.02
Office and IDTF | 2011 | 3,101,120 | 2,838,309 | 1.09 | 3,100,680 | 2,838,001 | 1.09 | 145,457 | 141,124 | 1.03 | 41,243 | 39,565 | 1.04
Office and IDTF | 2010 | 3,317,268 | 3,032,933 | 1.09 | 3,316,437 | 3,032,398 | 1.09 | 163,521 | 158,347 | 1.03 | 43,484 | 41,460 | 1.05
Office and IDTF | 2009 | 3,373,363 | 3,087,072 | 1.09 | 3,372,290 | 3,086,517 | 1.09 | 175,529 | 169,671 | 1.03 | 45,392 | 43,334 | 1.05
Office and IDTF | 2008 | 3,331,861 | 3,055,641 | 1.09 | 3,326,741 | 3,053,055 | 1.09 | 3,205,296 | 2,968,430 | 1.08 | 33,939 | 32,415 | 1.05
Office and IDTF | 2007 | 3,252,664 | 2,990,042 | 1.09 | 3,246,015 | 2,986,118 | 1.09 | 3,120,621 | 2,896,904 | 1.08 | 32,928 | 31,595 | 1.04
Office and IDTF | Total | 16,376,276 | 15,003,997 | 1.09 | 16,362,163 | 14,996,089 | 1.09 | 6,810,424 | 6,334,476 | 1.08 | 196,986 | 188,369 | 1.05
Other | 2011 | 19,030 | 17,960 | 1.06 | 19,016 | 17,946 | 1.06 | 119 | 119 | 1.00 | 35 | 35 | 1.00
Other | 2010 | 16,971 | 15,952 | 1.06 | 16,937 | 15,918 | 1.06 | 321 | 298 | 1.08 | 47 | 47 | 1.00
Other | 2009 | 20,372 | 19,260 | 1.06 | 20,345 | 19,234 | 1.06 | 414 | 395 | 1.05 | 39 | 39 | 1.00
Other | 2008 | 22,732 | 21,369 | 1.06 | 22,665 | 21,314 | 1.06 | 22,293 | 20,994 | 1.06 | 42 | 42 | 1.00
Other | 2007 | 24,886 | 23,314 | 1.07 | 24,833 | 23,267 | 1.07 | 24,366 | 22,842 | 1.07 | 46 | 46 | 1.00
Other | Total | 103,991 | 97,855 | 1.06 | 103,796 | 97,679 | 1.06 | 47,513 | 44,648 | 1.06 | 209 | 209 | 1.00

Appendix H Total allowed charges for echocardiography services, by specialty, 2007-2011

| | Allowed charges | Percent of total 5-year allowed charges per year
Total | 2011 | $1,619,452,595 | 18.9
Total | 2010 | $1,637,364,534 | 19.2
Total | 2009 | $1,613,483,353 | 18.9
Total | 2008 | $1,823,075,944 | 21.3
Total | 2007 | $1,858,228,298 | 21.7
Total | Total | $ 8,551,604,723 | 100.0
Cardiology | 2011 | $839,052,343 | 17.0
Cardiology | 2010 | $892,044,980 | 18.1
Cardiology | 2009 | $942,660,093 | 19.1
Cardiology | 2008 | $1,115,013,889 | 22.6
Cardiology | 2007 | $1,142,265,893 | 23.2
Cardiology | Total | $ 4,931,037,197 | 100.0
Outpatient facility | 2011 | $604,043,330 | 24.9
Outpatient facility | 2010 | $552,145,129 | 22.8
Outpatient facility | 2009 | $451,741,464 | 18.6
Outpatient facility | 2008 | $414,239,541 | 17.1
Outpatient facility | 2007 | $404,925,688 | 16.7
Outpatient facility | Total | $ 2,427,095,151 | 100.0
Internal medicine | 2011 | $104,992,715 | 14.4
Internal medicine | 2010 | $118,209,255 | 16.2
Internal medicine | 2009 | $134,980,887 | 18.5
Internal medicine | 2008 | $178,172,312 | 24.4
Internal medicine | 2007 | $193,742,365 | 26.5
Internal medicine | Total | 730,097,534 | 100.0
General / family practice | 2011 | $21,163,269 | 13.3
General / family practice | 2010 | $23,999,651 | 15.1
General / family practice | 2009 | $28,553,150 | 18.0
General / family practice | 2008 | $40,540,819 | 25.5
General / family practice | 2007 | $44,500,641 | 28.0
General / family practice | Total | 158,757,530 | 100.0
Independent Diagnostic Testing Facility (IDTF) | 2011 | $17,111,788 | 14.9
Independent Diagnostic Testing Facility (IDTF) | 2010 | $19,224,441 | 16.8
Independent Diagnostic Testing Facility (IDTF) | 2009 | $20,689,041 | 18.0
Independent Diagnostic Testing Facility (IDTF) | 2008 | $27,669,465 | 24.1
Independent Diagnostic Testing Facility (IDTF) | 2007 | $30,075,977 | 26.2
Independent Diagnostic Testing Facility (IDTF) | Total | 114,770,712 | 100.0
Diagnostic radiology | 2011 | $7,410,844 | 18.5
Diagnostic radiology | 2010 | $7,654,619 | 19.1
Diagnostic radiology | 2009 | $7,391,033 | 18.4
Diagnostic radiology | 2008 | $8,473,957 | 21.2
Diagnostic radiology | 2007 | $9,143,776 | 22.8
Diagnostic radiology | Total | $40,074,229 | 100.0
Other | 2011 | $25,678,307 | 17.1
Other | 2010 | $24,086,459 | 16.1
Other | 2009 | $27,467,684 | 18.3
Other | 2008 | $38,965,962 | 26.0
Other | 2007 | $33,573,958 | 22.4
Other | Total | $149,772,370 | 100.0

Appendix I Eligible beneficiaries receiving one or more echocardiography services, by State, 2007-2010

Map I1 Eligible beneficiaries receiving one or more echocardiography services, by State, 2010

Four U.S. maps showing percentage of eligible beneficiaries receiving one or more echocardiography services, by State, in 2007, 2008, 2009, and 2010. In all years, New York, New Jersey, and Florida had the highest percentage (25 to 30%) and States in the Mountain region and northern Midwest region had the lowest (10% to less than 15%).

Map I2 Eligible beneficiaries receiving one or more echocardiography services, by State, 2009

Four U.S. maps showing percentage of eligible beneficiaries receiving one or more echocardiography services, by State, in 2007, 2008, 2009, and 2010. In all years, New York, New Jersey, and Florida had the highest percentage (25 to 30%) and States in the Mountain region and northern Midwest region had the lowest (10% to less than 15%).

Map I3 Eligible beneficiaries receiving one or more echocardiography services, by State, 2008

Four U.S. maps showing percentage of eligible beneficiaries receiving one or more echocardiography services, by State, in 2007, 2008, 2009, and 2010. In all years, New York, New Jersey, and Florida had the highest percentage (25 to 30%) and States in the Mountain region and northern Midwest region had the lowest (10% to less than 15%).

Map I4 Eligible beneficiaries receiving one or more echocardiography services, by State, 2007

Four U.S. maps showing percentage of eligible beneficiaries receiving one or more echocardiography services, by State, in 2007, 2008, 2009, and 2010. In all years, New York, New Jersey, and Florida had the highest percentage (25 to 30%) and States in the Mountain region and northern Midwest region had the lowest (10% to less than 15%).

Appendix J Number of all eligible Medicare beneficiaries with one or more echocardiography services, by age and total, 2007-2011

| 2007 | 2008 | 2009 | 2010 | 2011
Total | 27,461,960 | 27,017,354 | 26,828,437 | 27,073,765 | 27,573,766
65-69 | 7,129,449 | 7,113,764 | 7,178,201 | 7,333,868 | 7,713,925
70-74 | 6,120,033 | 6,078,691 | 6,024,406 | 6,079,102 | 6,209,355
75-79 | 5,358,238 | 5,104,045 | 4,981,063 | 4,943,934 | 4,942,090
80-84 | 4,409,005 | 4,274,722 | 4,157,162 | 4,136,721 | 4,074,441
85+ | 4,445,235 | 4,446,132 | 4,487,605 | 4,580,140 | 4,633,955

Appendix K Percent of all eligible Medicare beneficiaries with one or more echocardiography service by age and total, 2007-2011

| 2007 | 2008 | 2009 | 2010 | 2011
Total | 19.7 | 20.2 | 20.4 | 20.4 | 20.1
65-69 | 13.5 | 13.8 | 14.0 | 13.9 | 13.4
70-74 | 18.2 | 18.7 | 19.0 | 19.1 | 18.8
75-79 | 22.1 | 22.6 | 22.8 | 22.9 | 22.7
80-84 | 24.6 | 25.4 | 25.7 | 25.9 | 25.7
85+ | 23.9 | 24.8 | 24.9 | 25.1 | 25.1

Appendix L Eligible urban and rural beneficiaries receiving one or more echocardiography services, by State, 2011

State | % of eligible Urban beneficiaries with 1+ echo service | % of eligible Rural beneficiaries with 1+ echo service
AK | 13.6 | 11.9
AL | 20.2 | 20.3
AR | 18.7 | 18.5
AZ | 20.8 | 14.0
CA | 21.3 | 16.2
CO | 14.6 | 12.8
CT | 19.7 | 25.0
DC | 22.9 | n/a
DE | 19.5 | 50.0
FL | 25.3 | 20.5
GA | 20.1 | 19.1
HI | 14.2 | n/a
IA | 16.2 | 14.8
ID | 12.8 | 12.4
IL | 19.4 | 16.9
IN | 17.9 | 16.6
KS | 18.1 | 16.7
KY | 19.6 | 20.4
LA | 22.5 | 20.3
MA | 18.2 | 15.6
MD | 20.3 | 16.0
ME | 16.6 | 15.8
MI | 24.0 | 19.2
MN | 14.7 | 13.5
MO | 18.5 | 17.7
MS | 19.6 | 17.7
MT | 15.6 | 14.1
NC | 18.1 | 16.4
ND | 14.6 | 14.3
NE | 18.8 | 17.4
NH | 16.9 | 16.3
NJ | 26.5 | 23.1
NM | 15.0 | 13.6
NV | 22.6 | 14.3
NY | 27.5 | 20.5
OH | 18.7 | 18.1
OK | 18.3 | 18.6
OR | 13.2 | 12.2
PA | 21.0 | 19.7
PR | 19.3 | 14.1
RI | 19.7 | n/a
SC | 19.1 | 19.1
SD | 14.5 | 12.9
TN | 17.7 | 19.6
TX | 21.1 | 19.2
UT | 14.9 | 11.0
VA | 17.2 | 17.0
VT | 14.0 | 12.7
WA | 14.6 | 14.1
WI | 16.0 | 13.7
WV | 18.3 | 19.5
WY | 13.8 | 12.7