# Data Points # 17 Trends in bariatric surgery in Medicare beneficiaries

Use of bariatric surgery increased dramatically in Medicare beneficiaries from 2006 through 2009.

Procedure mix varies by age and region and changed over the period of analysis as laparoscopic operations became more common.

Most Medicare bariatric surgery recipients are under age 65 (eligible due to disability), but the proportion of recipients over 65 has increased over time.

Rehospitalization rates are moderate and relatively stable over time. Postoperative mortality is low.

Bariatric surgery is not associated with disenrollment from the Medicare program among working age disabled beneficiaries. Only about one percent of disabled people who received bariatric surgery disenrolled within five years of the procedure.

Obesity has been associated with a number of comorbidities and adverse health outcomes and is considered one of the major challenges facing the health care system today.1 In 2008, more than one-third of the adult population was obese,2 defined as having a body mass index (BMI) of 30 kg/m^2^ or higher. Research has shown surgical treatments to be more effective for weight loss than nonsurgical strategies such as diet and exercise or pharmacotherapy.3,4

Bariatric procedures result in weight loss by modifying the size of the stomach (restriction) or the anatomy of the small intestine (malabsorption). 3 The most common operation for weight loss performed in the United States, the Roux-en-Y gastric bypass (RYGB), is both a restrictive and a malabsorptive operation. RYGB is performed by creating a small gastric pouch, usually <30 mL, and rerouting the intestine such that the duodenum and proximal jejunum are bypassed. It is most often performed laparoscopically (LRYGB) but can also be carried out with an open approach (ORYGB) when indicated. Another option is the adjustable gastric band (AGB), a purely restrictive approach. It reduces stomach size through the use of a mechanical device placed over the proximal portion of the stomach. Finally, biliopancreatic diversion with duodenal switch (DS), the most malabsorptive operation, bypasses most of the duodenum and all of the jejunum, and provides only about a 100 cm common channel in the distal ileum for both consumed nutrients and biliopancreatic secretions to mix and be absorbed.3

Each operation provides different but significant degrees of weight loss. In addition, studies have demonstrated significant improvements in medical comorbidities such as type 2 diabetes, obstructive sleep apnea, and hypertension following bariatric surgeries.5,6 Bariatric surgery is not risk free, however. Morbidity and mortality rates following bariatric surgery continue to be a major concern.7

Medicare provides health insurance to people over age 65 and to working-age disabled people. As observed in the general population, obesity is common in Medicare beneficiaries. In 2002, 21.4 percent of older beneficiaries and 39.3 percent of disabled beneficiaries were considered obese.8 These numbers have likely increased over time.9 As the number of obese Medicare beneficiaries increases, so does the number eligible for bariatric surgery.

Beginning in February 2006, the Centers for Medicare & Medicaid Services (CMS) expanded coverage of bariatric operations. Beneficiaries with a BMI of 35 kg/m^2^ or greater and at least one obesity-related comorbidity who have documented unsuccessful medical treatment for their obesity become eligible to receive bariatric surgery. Medicare covers ORYGB or LRYGB, open or laparoscopic DS, or laparoscopic adjustable gastric banding in an inpatient (IPLAGB) or outpatient (OPLAGB) setting at a Level 1 Bariatric Surgery Center or Bariatric Surgery Center of Excellence.10 This report describes the use and associated outcomes of bariatric surgery by Medicare beneficiaries from 2006 through 2009.

## METHODS

### Cohort

We identified all Medicare beneficiaries, both working-age disabled and age eligible, who received one of five bariatric operations from 2006 through 2009. We defined our operations using CMS Healthcare Common Procedure Coding System (HCPCS) codes in the Carrier data: 43644–43645 for LRYGB; 43845 for laparoscopic DS; 43770 for LAGB, both inpatient and outpatient; and 43846–43847 for ORYGB. Patients must have been enrolled in Medicare Parts A and B at the time of the operation.

Carrier claims must have been matched to an inpatient or outpatient claim and be accompanied by a diagnosis of morbid obesity (278.01) or a reported BMI of at least 35 kg/m^2^ (V85.35–V85.39, V85.4X). More than 95 percent of claims for these procedures were accompanied by these diagnosis codes. Denied claims were excluded.

### Analysis

We assessed trends in procedure type across years (2006 to 2009; Table 1) and demographic factors, including age, race, sex, and geographic region (West, Southwest, Midwest, Northeast, Southeast). These characteristics were all identified in the beneficiary summary file during the year the operation took place. We further distinguish beneficiaries who are eligible for Medicare due to disability (those less than 64 years of age) or age (65 years and older).

Table 1 Number of bariatric operations received by Medicare beneficiaries, 2006–2009

| Total | LRYGB | IPLAGB | OPLAGB | DS | ORYGB
Total | 37,799 | 19,584 | 13,746 | 588 | 399 | 3,482
2006 | 5,605 | 3,140 | 1,325 | 55 | 33 | 1,052
2007 | 8,420 | 4,311 | 2,952 | 117 | 76 | 964
2008 | 11,054 | 5,492 | 4,431 | 205 | 137 | 789
2009 | 12,720 | 6,641 | 5,038 | 211 | 153 | 677

LRYGB: laparoscopic Roux-en-Y gastric bypass; IPLAGB: inpatient laparoscopic adjustable gastric banding; OPLAGB: outpatient laparoscopic adjustable gastric banding; DS: laparoscopic biliopancreatic diversion with duodenal switch; ORYGB: open Roux-en-Y gastric bypass.

The outcomes we studied included hospital length of stay (LOS), rehospitalization rates, one-year mortality, and disenrollment from Medicare for the disabled beneficiaries. LOS was measured from admission to discharge. Rehospitalization within 30 days was identified as any admission within 30 days from discharge, except in the case of OPLAGB, where rehospitalization was identified as any admission within 30 days of the outpatient operation.

We used Kaplan-Meier survival estimates11 to measure survival following bariatric surgery (censoring at the end of the observation period) and loss of disability benefits among working-age disabled people (censoring when the beneficiary reached age 65, died, or reached the end of our observation period).

## RESULTS

Our analysis of CMS claims resulted in 37,799 Medicare beneficiaries who underwent one of five bariatric operations from 2006 through 2009. The most common procedure was LRYGB (19,584, 51.8%), followed by IPLAGB (13,746, 36.4%), ORYGB (3,482, 9.2%), OPLAGB (588, 1.6%), and DS (399, 1.1%; Table 1). Over the period of our study, bariatric surgery more than doubled, from 5,605 cases in 2006 to 12,720 cases in 2009. Use of LRYGB, IPLAGB, OPLAGB, and DS increased over time, while use of ORYGB decreased (Table 1). Overall, more whites than any other race/ethnicity received bariatric surgery, and rates of surgery were highest in the Midwest and Southeast regions (Table 2).

Table 2 Percent distribution of patient demographics among Medicare beneficiaries who received bariatric surgery for morbid obesity, by type of surgery, 2006–2009

| Overall | LRYGB | IPLAGB | OPLAGB | DS | ORYGB
Total | 100.0 | 100.0 | 100.0 | 100.0 | 100.0 | 100.0
Age (years)
Disabled Beneficiaries
18 – 34 | 6.6 | 8.0 | 4.1 | 4.3 | 11.8 | 8.1
35 – 44 | 15.6 | 18.0 | 11.1 | 11.2 | 18.8 | 19.8
45 – 54 | 24.1 | 27.2 | 18.8 | 16.8 | 29.1 | 28.7
55 – 64 | 25.8 | 26.0 | 25.5 | 22.5 | 25.8 | 26.1
Older Beneficiaries
65 – 66 | 12.0 | 10.1 | 15.5 | 18.0 | 7.3 | 8.6
67 – 70 | 12.1 | 8.7 | 18.0 | 20.6 | 6.0 | 7.0
71+ | 3.8 | 2.0 | 6.9 | 6.6 | 1.3 | 1.6
Sex
Male | 25.5 | 24.1 | 27.1 | 24.0 | 35.6 | 26.7
Race
White | 81.9 | 80.7 | 83.4 | 84.2 | 85.5 | 81.4
Black | 14.2 | 15.0 | 13.2 | 14.5 | 9.0 | 14.5
Other | 3.9 | 4.4 | 3.4 | 1.4 | 5.5 | 4.1
Region
Midwest | 27.2 | 29.6 | 22.6 | 18.7 | 54.9 | 30.4
Northeast | 18.3 | 16.0 | 18.6 | 41.5 | 9.5 | 26.5
Southeast | 27.1 | 27.8 | 27.6 | 16.0 | 11.5 | 24.2
Southwest | 12.9 | 11.3 | 16.2 | 13.1 | 4.0 | 10.5
West | 14.5 | 15.3 | 15.0 | 10.7 | 20.1 | 8.4

LRYGB: laparoscopic Roux-en-Y gastric bypass; IPLAGB: inpatient laparoscopic adjustable gastric banding; OPLAGB: outpatient laparoscopic adjustable gastric banding; DS: laparoscopic biliopancreatic diversion with duodenal switch; ORYGB: open Roux-en-Y gastric bypass. Percentages may not add to 100 due to rounding.

Bariatric operations were performed on more disabled beneficiaries than older adults, although over time, this majority decreased (Figure 1). The youngest patients, ages 18–34, were most likely to undergo LRYGB (63.1%) of any operation. This procedure became less common with each increasing age group, with only 26.8 percent of those over 70 receiving LRYGB. A similar trend was observed with ORYGB and DS (from 11.3% to 4.0% and 1.9% to 0.3%, respectively, across increasing age groups; Figure 2a). Alternatively, IPLAGB rates consistently increased as patients aged, from 22.7 percent of operations in the youngest patients to 66.2 percent of those in patients over 70, as did rates of OPLAGB (1.0% to 2.7%; Figure 2a).

Figure 1 Proportion of Medicare beneficiaries receiving bariatric surgery who were disabled, by type of surgery, 2006–2009

Figure shows the percent of disabled beneficiaries receiving different types of bariatric surgery in 2006–2009. In most categories, the use of bariatric surgery decreases between 2006 and 2009. Use of DS decreased from 2006 to 2008, but increased in 2009.

Figure 2 Distribution of bariatric operations among Medicare disabled and elderly beneficiaries, by age, sex, race/ethnicity, and region, 2006–2009

Figure 2a: Use of bariatric surgery by age. LRYGB and IPLAGB are the most commonly used surgery types in all ages. 60% of 18–34 year olds use LRYGB, and use of LYRGB decreases as age increases. Use of IPLAGB increases as age increases, with about 60% of people aged 71 and over used IPLAGB. Figure 2b: Distribution of bariatric operations by sex. Males and females have a similar distribution of use of types of surgery. About 50% of males and females use LRYGB, 30% use IPLAGB, and 10% use ORYGB. Figure 2c: Distribution of bariatric operations by race and ethnicity. The distribution of operations is fairly constant across races, including Black, White, Asian, Hispanic, American Indian, and Other. Approximately 50% of people across racial/ethnic categories use LRYGB, 30% use IPLAGB, and 10% us ORYGB. Figure 2d: Distribution of bariatric operations by geographic region. The distribution of use of different types of surgery across regions is fairly constant. Approximately 50% use LYRGB, 30% use IPLAGB, and 10% use ORYGB across the Midwest, Northeast, Southeast, Southwest, and West.

Males and females followed the same patterns in procedure choice: LRYGB was the most common, followed by IPLAGB, ORYGB, OPLAGB, and DS. Females were slightly more likely to undergo LRYGB (52.8%) than males (48.9%; Figure 2b).

LRYGB was again the most common bariatric procedure performed on patients of all races. It was most common in Hispanic patients, who were less likely than other patients to receive LAGB (Figure 2c).

### Geographic Variation

Most Medicare bariatric procedures occurred in the Midwest (27.2%) and Southeast (27.1%) regions, followed by the Northeast (18.3%), West (14.5%), and Southwest (12.9%). Bariatric procedure mix varied by region. LRYGB was most common in all regions (45.2%–56.3% of operations) other than in the Southwest region, where it was as common as IPLAGB. OPLAGB was most common in the Northeast region (3.5%) and least common in the Southeast (0.9%). ORYGB was almost twice as common in the Midwest (10.3%) as the West (5.3%). DS was the least common inpatient procedure, ranging from 0.3 percent of cases in the Southwest to 2.1 percent of cases in the Midwest (Figure 2d).

### Outcomes

Overall, median length of stay (LOS) was 3 days, with 8.8 percent being rehospitalized within 30 days (Table 3). Rehospitalization rates did not vary between males (8.8%) and females (8.9%). Both sexes experienced higher (>15%) rehospitalization rates following DS or ORYGB procedures than following LRYGB (9.7–10.6%) or LAGB (3.1–6.0%; Figure 3a). Rehospitalization rates varied more when stratified by age group (Figure 3b) and by race. Black patients were more likely to be rehospitalized within 30 days than whites in total (11.4% vs. 8.6%) and for each procedure (Figure 3c). Mortality was low—0.5 percent at 30 days and 1.6 percent within 1 year (Table 3).

Table 3 Patient outcomes among Medicare beneficiaries receiving bariatric surgery for morbid obesity, by type of surgery, 2006–2009

| Overall | LRYGB | IPLAGB | OPLAGB | DS | ORYGB
Median LOS (Days) | 3 | 3 | 2 | n/a | 5 | 4
| % | % | % | % | % | %
30-day rehospitalization^*^ | 8.8 | 10.4 | 5.1 | 3.7^*^ | 16.6 | 15.4
30-day mortality | 0.5 | 0.6 | 0.2 | 0.2 | 0.8 | 0.2
1-year mortality: Total | 1.6 | 1.7 | 0.8 | 0.7 | 4.0 | 3.1
1-year mortality: Men | 2.1 | 2.2 | 1.5 | 0.7 | 3.5 | 4.4
1-year mortality: Women | 1.3 | 1.5 | 0.6 | 0.7 | 4.3 | 2.5
Disenrollment from Medicare disability benefit within 3 years^†^ | 0.64 | 0.69 | 0.56 | 0.0 | 1.2 | 0.59

* Hospitalization within 30 days of outpatient operation.

† Kaplan-Meier methods used. Observations were censored at beneficiary reaching 65 years of age; December 31, 2010; and death.

LRYGB: laparoscopic Roux-en-Y gastric bypass; IPLAGB: inpatient laparoscopic adjustable gastric banding; OPLAGB: outpatient laparoscopic adjustable gastric banding; DS: laparoscopic biliopancreatic diversion with duodenal switch; ORYGB: open Roux-en-Y gastric bypass.

Figure 3 Medicare older and disabled beneficiaries requiring 30-day readmission following bariatric surgery, by type of operation and sex, age, and race, 2006–2009

^*^ DS and OPLAGB not reported due to small numbers.

LRYGB: laparoscopic Roux-en-Y gastric bypass; IPLAGB: inpatient laparoscopic adjustable gastric banding; OPLAGB: outpatient laparoscopic adjustable gastric banding; DS: laparoscopic biliopancreatic diversion with duodenal switch; ORYGB: open Roux-en-Y gastric bypass.

Figure 3a: Medicare older and disabled beneficiaries requiring 30-day readmission by Sex. All types of surgery had less than 25% readmission rates, and distribution of readmission by surgery is similar between males and females. DS and ORYGB have the highest rates of readmission at around 15%. Figure 3b: Medicare older and disabled beneficiaries requiring 30-day readmission following bariatric surgery by Age. All types of surgery had less than 25% readmission rates, and distribution of readmission by surgery is similar across ages. LRYGB and ORYGB have higher readmission rates (approximately 10% and 15% respectively) than IPLAGB (approximately 5%). Figure 3c: Medicare older and disabled beneficiaries requiring 30-day readmission following bariatric surgery by race. Rates of readmission for whites are approximately 10% for LRYGB, 5% for IPLAGB, and 15% for ORYGB. Rates of readmission for blacks are slightly higher, at approximately 15% for LRYGB, 5% for IPLAGB, and 20% for ORYGB.

Outcomes differed by operation, with the best outcomes observed in patients undergoing LAGB and the worst in those who had DS (Figure 4). Elderly and disabled beneficiaries had similar survival curves, with 95 percent surviving five years (Figure 5).

Figure 4 Rate of death following bariatric surgery among Medicare beneficiaries, by type of operation, at 30 days and 1 year, 2006–2009

Note: Figure shown on 0% to 5% scale.

LRYGB: laparoscopic Roux-en-Y gastric bypass; IPLAGB: inpatient laparoscopic adjustable gastric banding; OPLAGB: outpatient laparoscopic adjustable gastric banding; DS: laparoscopic biliopancreatic diversion with duodenal switch; ORYGB: open Roux-en-Y gastric bypass.

Figure 4 shows that mortality is less than 5% for all types of surgery at either 30 days or 1 year. Mortality rates at 30 days post surgery are approximately 0.25% for IPLAGB, OPLAGB, and ORYGB, 0.5% for LRYGB, and 0.75% for DS. Mortality rates at 1 year past surgery are highest for DS at 4%, followed by ORYGB at 3%, LRYGB at 1.5%, and IPLAGB and OPLAGB at about 0.75%.

Figure 5 Kaplan-Meier curve describing the survival of Medicare beneficiaries following bariatric surgery, by type of Medicare eligibility, 2006–2009^*^

^*^ Events censored at the end of the observation period (December 31, 2010).

Note: Figure shown on 90% to 100% scale.

LRYGB: laparoscopic Roux-en-Y gastric bypass; IPLAGB: inpatient laparoscopic adjustable gastric banding; OPLAGB: outpatient laparoscopic adjustable gastric banding; DS: laparoscopic biliopancreatic diversion with duodenal switch; ORYGB: open Roux-en-Y gastric bypass.

Figure 5 shows survival rates post-bariatric surgery for both aged and disabled beneficiaries. Both beneficiary populations have a similar survival pattern, with survival decreasing from 100% at 0 months to about 95% at 60 months (5 years).

Of note, one-year mortality was five times higher for DS patients than for IPLAGB or OPLAGB (4.0% vs. 0.7–0.8%; Table 3 and Figure 6). DS had the worst associated survival, and OPLAGB the best (Figure 6). Outcomes varied slightly over the period of analysis (Figures 7, 8a, and 8b).

Figure 6 Kaplan-Meier curve describing the survival of Medicare beneficiaries following bariatric surgery, by type of operation, 2006–2009^*^

^*^ Events censored at the end of the observation period (December 31, 2010).

Note: Figure shown on 90% to 100% scale.

LRYGB: laparoscopic Roux-en-Y gastric bypass; IPLAGB: inpatient laparoscopic adjustable gastric banding; OPLAGB: outpatient laparoscopic adjustable gastric banding; DS: laparoscopic biliopancreatic diversion with duodenal switch; ORYGB: open Roux-en-Y gastric bypass.

Figure 6 shows survival rates post-bariatric surgery by type of surgery. Survival decreases over time for all types of surgery, but does not go below 94% over a 5-year period. Survival rates are worst for DS, followed by ORYGB, LRYGB, IPLAGB, and OPLAGB. OPLAGB has the highest survival rate at 97% after 5 years.

Figure 7 Rate of Medicare beneficiaries requiring 30-day readmission following bariatric surgery, by type of operation and year, 2006–2009

Note: Figure shown on 0% to 25% scale.

LRYGB: laparoscopic Roux-en-Y gastric bypass; IPLAGB: inpatient laparoscopic adjustable gastric banding; OPLAGB: outpatient laparoscopic adjustable gastric banding; DS: laparoscopic biliopancreatic diversion with duodenal switch; ORYGB: open Roux-en-Y gastric bypass.

Figure 7 shows readmission rates within 30 days of operation by type of bariatric surgery between 2006 and 2009. Readmission rates are lowest overall for OPLAGB, followed by IPLAGB, LRYGB, ORYGB, and DS. Over time, rates for LRYGB and IPLAGB remain constant, while rates for ORYGB increase slightly from 15 to 18%. Readmission rates increase for OPLAGB from 0% in 2006 to 5% in 2008, and decrease again to about 4 % in 2009. Readmission rates for DS increase slighthly from 16 to 16% between 2006 and 2007, decrease to about 12% in 2008, and then jump to about 22% in 2009.

Figure 8 Medicare beneficiaries who died within 30 days and 1 year following bariatric surgery, by type of operation and year, 2006–2009

Note: Figures shown on 0% to 10% scale.

LRYGB: laparoscopic Roux-en-Y gastric bypass; IPLAGB: inpatient laparoscopic adjustable gastric banding; OPLAGB: outpatient laparoscopic adjustable gastric banding; DS: laparoscopic biliopancreatic diversion with duodenal switch; ORYGB: open Roux-en-Y gastric bypass.

Figure 8a shows 30 day mortality rates post-bariatric surgery between 2006 and 2009. The mortality rate for all types of surgery decreased from 2006 to 2009, with LRYGB, IPLAGB, OPLAGB, and ORYGB surgery mortality rates remaining under 2%. The DS mortality rate decreased from 3% to 1.5% between 2006 and 2009. Figure 8b shows 1 year mortality rates post-bariatric surgery between 2006 and 2009. Rates for IPLAGB and LRYGB remain fairly constant at under 2%. Rates for OPLAGB increase from 0% to about 3.5% from 2006 to 2008 and decrease to 0.5% in 2009. Rates for ORYGB increase slightly from 3 to about 3.8% between 2006 and 2007, decrease to 0.5% in 2008, and increase to 2.5% in 2009. Rates for DS decrease from about 6% to 2 % between 2006 and 2008, and increase to about 4.3% in 2009.

### Medicare Disenrollment for the Working-Age Disabled

Disenrollment for working-age disabled beneficiaries following bariatric surgery was low; fewer than one percent (0.64%) had disenrolled three years after the operation (Figure 9a). Rates of disenrollment at three years after surgery varied slightly by type of operation (1.2% for DS and 0.69% for LRYGB; Table 3 and Figure 9b).

Figure 9 Kaplan-Meier curve describing the disenrollment of disabled Medicare beneficiaries following bariatric surgery, overall and by type of operation, 2006–2009^*^

^*^ Events censored at the end of the observation period (December 31, 2010), when the patient reached age 65, and at death.

Note: Figures shown on 95% to 100% scale.

LRYGB: laparoscopic Roux-en-Y gastric bypass; IPLAGB: inpatient laparoscopic adjustable gastric banding; OPLAGB: outpatient laparoscopic adjustable gastric banding; DS: laparoscopic biliopancreatic diversion with duodenal switch; ORYGB: open Roux-en-Y gastric bypass.

Figure 9a shows overall enrollment of disabled Medicare beneficiaries following bariatric surgery between 0 and 60 months after operation. Enrollment decreases very slightly over time from 100% enrollment at time of surgery to 99%. Figure 9b shows enrollment of disabled Medicare beneficiaries following bariatric surgery by operation type between 0 and 60 months after operation. Enrollment decreases very slightly over time from 100% enrollment at time of surgery to about 98.5%. DS has the highest decrease in enrollment reaching 98.5%, followed by LRYGB, ORYGB, and IPLAGB which reaches 99.5%. OPLAGB remains at 100% enrollment over time.

## DISCUSSION

We found that bariatric surgery greatly increased in the Medicare program following reimbursement expansion in February 2006, more than doubling through 2009. Procedure mix varied across patient factors, geography, and time, with laparoscopic operations becoming more common throughout the period studied.

The proportion of patients receiving LRYGB decreased with patient age, and the proportion of elderly Medicare recipients undergoing LAGB increased concomitantly, similar to previously reported findings.12

Many surgeons may feel that LAGB is more suitable for older patients because it is comparatively shorter, requires fewer hospital days, and does not require an intestinal anastomosis to be performed. However, we found that older patients receiving RYGB did not require more readmissions than younger patients who underwent the same procedure (Figure 3b).

The geographic differences in procedure mix may be explained by the degree of obesity present in different regions of the country. The Midwest and Southeast regions of the United States have higher rates of obesity compared to the Northeast and Southwest according to the Centers for Disease Control and Prevention13; the degree of obesity may vary between these regions as well. Patients with a higher BMI (i.e., ≥45 kg/m^2^) may be more likely to undergo RYGB, because the degree of weight loss experienced will be greater than that achieved by the gastric band.14,15

Observed mortality rates were low: under 1 percent for all operations at 30 days postoperation and 4 percent or less at one year. Prior to the current Medicare coverage rules becoming effective in 2006, David Flum and colleagues investigated bariatric procedure use and related mortality in Medicare beneficiaries between 1997 and 2002.^16^ They found higher mortality rates—2.0 percent mortality at 30 days and 4.6 percent mortality at one year. However, due to the years studied, laparoscopic procedures were not included in their analysis. Since then, bariatric surgery has become safer due to a combination of factors that include, but are not limited to, increased use of the laparoscopic approach, achievement of the learning curve as bariatric surgeons have gained more experience, and more regimented fellowship training programs.

Other work since has observed lower mortality rates more similar to what we have reported here.7,12,17–19

We found that younger disabled beneficiaries received most of the Medicare bariatric operations as was observed in 2001–2002, prior to the 2006 coverage expansion.17 Among the older Medicare population, we found that a high percentage of bypass recipients were age 65 or 66. This might be interpreted as a sign of pent-up demand for gastric bypass surgeries and suggests that some beneficiaries may be postponing surgery until they become Medicare eligible. Further work is needed to investigate this pattern.

Ideally, bariatric surgery should result in decreased weight-related comorbidities and increased ability to work, thereby reducing the need for disability benefits. Weight-related comorbidities may be preventing some disabled beneficiaries’ employment, as these comorbidities are common in bariatric patients. In fact, Doshi and colleagues found that 85 percent of obese disabled beneficiaries had at least one comorbidity.8

Research has documented decreased comorbidities following bariatric surgery.6 One study observed a 51 percent decrease in weight-related comorbidities following bariatric surgery and resolved joint pain in 30 percent of patients. Further, the authors found that weight loss following bariatric surgery increased independence, ability to be active members of society, quality of life, and medical health20 while others observed a decrease in the use of drugs for obesity-related conditions.1 However, we saw very low disenrollment for Medicare disabled beneficiaries following bariatric surgery; approximately 99 percent of disabled beneficiaries continued to be enrolled in Medicare due to disability five years post-bariatric surgery.

This finding may be due, in part, to some obese beneficiaries having other disabilities (e.g., mental health problems).8 Investigation into the effect of bariatric surgery on ability to obtain gainful employment is warranted.

This report is limited to services covered by Medicare from 2006 through 2009. Thus, the following procedures were not included: open adjustable gastric banding, open and laparoscopic sleeve gastrectomy, open and laparoscopic vertical banded gastroplasty, and gastric balloon. Also, bariatric operations performed at facilities other than Level 1 Bariatric Surgery Centers or Bariatric Surgery Centers of Excellence are not included.10 Finally, while all patients in our cohort were morbidly obese, further BMI analysis within our population was not possible as BMI is not included in CMS data. We cannot estimate population rates of bariatric surgery as we do not have information on the prevalence of morbid obesity in the Medicare elderly or disabled populations. Thus, it is not possible to comment on the percentage of obese persons undergoing bariatric surgery or assess whether surgery is more commonly used in some population subgroups than others.

## CONCLUSION

Use of bariatric surgery in Medicare patients has dramatically increased since its expansion of coverage in 2006. We observed increases in operations in both the age-eligible and working-age disabled groups. Most operations were performed on disabled beneficiaries, but the proportion of age-eligible operations increased over time. While mortality was relatively low and rehospitalization rates moderate, it did not appear that bariatric surgery was associated with health status improvements great enough to warrant return to the workforce.

## Acknowledgments

The authors wish to thank Jessica Zeglin and Mary A. Leonard for their graphic design expertise.

This project was funded under Contract No. HHSA29020100013I from the Agency for Healthcare Research and Quality, U.S. Department of Health and Human Services as part of the Developing Evidence to Inform Decisions about Effectiveness (DEcIDE) program. The authors of this report are responsible for its content. Statements in the report should not be construed as endorsement by the Agency for Healthcare Research and Quality or the U.S. Department of Health and Human Services. We received approval for this analysis from the University of Minnesota Institutional Review Board (IRB) and CMS. Data have been managed and reported in accordance with data use agreement number 21399.

## REFERENCES

1 Segal JB, Clark JM, Shore AD, et al. (2009). Prompt reduction in use of medications for comorbid conditions after bariatric surgery. Obes Surg.
2 Flegal KM, Carroll MD, Ogden CL, et al. (2010). Prevalence and trends in obesity among U.S. adults, 1999–2008. JAMA.
3 Shekelle PG, Morton SC, Maglione M, et al. (2004). Pharmacological and surgical treatment of obesity, Evidence Report/Technology Assessment No. 103.
4 Sjöström L, Narbro K, Sjöström CD, et al. (2007). Effects of bariatric surgery on mortality in Swedish obese subjects. New Engl J Med.
5 Sjöström C, Lissner L, Wedel H, et al. (1999). Reduction in incidence of diabetes, hypertension and lipid disturbances after intentional weight loss induced by bariatric surgery: the SOS Intervention Study. Obes Res.
6 Buchwald H, Avidor Y, Braunwald E, et al. (2004). Bariatric surgery: a systematic review and meta-analysis. JAMA.
7 Zhao Y, Encinosa W. (2007). Bariatric surgery utilization and outcomes in 1998 and 2004, Statistical Brief #23.
8 Doshi JA, Polsky D, Chang VW. (2007). Prevalence and trends in obesity among aged and disabled U.S. Medicare beneficiaries, 1997–2002. Health Aff.
9 Arterburn DE, Crane PK, Sullivan SD. (2004). The coming epidemic of obesity in elderly Americans. J Am Geriatr Soc.
10 (2006). CMS decision memo for bariatric surgery for the treatment of morbid obesity (CAG-00250R).
11 Klein JP, Moeschberger ML. (2003). Survival analysis: Techniques for censored and truncated data.
12 Dorman RB, Abraham AA, Al-Refaie WB, et al. (2012). Bariatric surgery outcomes in the elderly: an ACS NSQIP study. J Gastrointest Surg.
13 Centers for Disease Control and Prevention. Adult Obesity Facts.
14 Puzziferri N, Nakonezny PA, Livingston EH, et al. (2008). Variations of weight loss following gastric bypass and gastric band. Ann Surg.
15 Dorman RB, Serrot FJ, Miller CJ, et al. (2012). Case-matched outcomes in bariatric surgery for treatment of type 2 diabetes in the morbidly obese patient. Ann Surg.
16 Flum DR, Salem L, Elrod JAB, et al. (2005). Early mortality among Medicare beneficiaries undergoing bariatric surgical procedures. JAMA.
17 Livingston EH, Langert J. (2006). The impact of age and Medicare status on bariatric surgical outcomes. Arch Surg.
18 Flum DR, Kwon S, Macleod K, et al. (2011). The use, safety and cost of bariatric surgery before and after Medicare’s national coverage decision. Ann Surg.
19 Nguyen NT, Hohmann S, Slone J, et al. (2010). Improved bariatric surgery outcomes for Medicare beneficiaries after implementation of the Medicare national coverage determination. Arch Surg.
20 Fatima J, Houghton SG, Iqbal CW, et al. (2006). Bariatric surgery at the extremes of age. J Gastrointest Surg.

## APPENDICES

Appendix A Number of Medicare beneficiaries who received bariatric surgery for morbid obesity, by patient demographics and type of surgery, 2006–2009

| Total | LRYGB | IPLAGB | OPLAGB | DS | ORYGB
Age (years)
Disabled Beneficiaries
18 – 34 | 2,494 | 1,574 | 567 | 25 | 47 | 281
35 – 44 | 5,885 | 3,528 | 1,525 | 66 | 75 | 691
45 – 54 | 9,122 | 5,320 | 2,587 | 99 | 116 | 1,000
55 – 64 | 9,742 | 5,090 | 3,508 | 132 | 103 | 909
Elderly Beneficiaries
65 – 66 | 4,551 | 1,979 | 2,136 | 106 | 29 | 301
67 – 70 | 4,566 | 1,707 | 2,471 | 121 | 24 | 243
71+ | 1,439 | 386 | 952 | * | * | 57
Sex
Male | 9,648 | 4,716 | 3,720 | 141 | 142 | 929
Female | 28,151 | 14,868 | 10,026 | 447 | 257 | 2,553
Race
White | 30,931 | 15,795 | 11,465 | 495 | 341 | 2,835
Black | 5,368 | 2,929 | 1,812 | 85 | 36 | 506
Other | 1,487 | 854 | 462 | * | * | 141
Region
Midwest | 10,281 | 5,791 | 3,104 | 110 | 219 | 1,059
Northeast | 6,902 | 3,141 | 2,557 | 244 | 38 | 923
Southeast | 10,228 | 5,450 | 3,795 | 94 | 46 | 843
Southwest | 4,891 | 2,211 | 2,223 | 77 | 16 | 365
West | 5,492 | 2,990 | 2,067 | 63 | 80 | 292

* Omitted due to small cell size.

Totals are derived from rates and may not sum exactly due to rounding.