# Results

## Literature Review and Screening

The electronic literature search identified 6,961 unique citations. After the first level of screening based on title and abstract 6,441 articles were excluded from further review, leaving 520 articles for full-text retrieval. We identified an additional 14 studies through hand searching and contact with content experts. Of the 534 articles identified, 34 could not be located in either the University of Alberta libraries' holdings or through interlibrary loan requests. Of the 499 articles reviewed at the second level of screening, 16 addressed Key Question 1a. Eleven of these studies used validated measures to evaluate health-related quality of life (HRQL) and were applicable to Key Question 1b. Nine unique studies met our inclusion criteria to address Key Questions 2 and 3. Two of these studies41,42 each had a related publication.43,44 Figure 2 depicts the flow of the studies through the screening process and provides a breakdown of reasons for exclusion (see Appendix C for a list of excluded studies).

Figure 2 Flow diagram for study retrieval and selection

## Key Question 1a What HRQL measures have been used in studies of treatments for diabetic retinopathy?

We identified four HRQL measures that have been used in studies assessing the treatment of diabetic retinopathy (DR). The most commonly used measure was the National Eye Institute Visual Functioning Questionnaire (VFQ), which is available in two versions. Five studies41,42,45-47 used the 25 item version (VFQ–25); one48 used the 51-item version (VFQ-51). In addition, seven recently completed trials that have not yet published their results reported using the VFQ–25 (See Appendix A for trial registration numbers). One study49 used both the VFQ–25 and the Medical Outcomes Study (MOS) 36–Item Short Form Health Survey (SF–36). Two studies50,51 used the Visual Function Index (VF–14). One study used both the VF–14 and the MOS 12-Item Short Form Health Survey (SF–12)52, and another study53 used the VF–14 plus a questionnaire to assess satisfaction with surgical outcomes. One study54 used the Diabetes Treatment Satisfaction Questionnaire (DTSQ) plus a questionnaire to assess the degree to which treatment outcomes corresponded to patient expectations. One study55 used qualitative interviews to assess quality of life but did not use a specific measure.

In addition to the measures used in studies of treatment for DR, we also identified two HRQL measures that have been developed specifically for patients with DR: the Retinopathy Treatment Satisfaction Questionnaire (RetTSQ), and the Retinopathy Dependent Quality of Life (RetDQoL) measure. Currently there is no literature describing their use in the evaluation of treatments for DR.

## Key Question 1b What are the psychometric properties of the HRQL measures used in the studies?

The six HRQL tools can be separated into two broad groups: generic tools and specific tools. The latter category can be further divided into tools developed for use in populations with: low vision, diabetes mellitus, and DR. See Appendix D for a description of the six measurement tools. Table 1 presents the psychometric properties of the measures. The ratings of the measurement properties based on the Consensus-based Standards for the selection of health Measurement INstruments (COSMIN) checklist are shown in Table 2. Below is a summary description of each tool.

Table 1 Psychometric properties of health-related quality of life assessment tools used in studies of the treatment of diabetic retinopathy

Measure | Study population | Construct validity | Internal consistency | Test-retest reliability | Responsiveness
Generic HRQL assessment tools
SF–36^56,57,72^ | Patients who participated in the Medical Outcomes Study (1986) (US); differed in SES, medical and psychiatric dx and disease severity | 7 scales (excluding general health) explain two-thirds of reliable variance in evaluations of current health status in UK, U.S., and Sweden; Scales have demonstrated 80–90% empirical validity in studies involving physical and mental health criteria compared with the longer MOS; Validity of each scale has been shown to differ from other scales: Physical functioning (r = 0.85), role-physical (r = 0.81) and bodily pain scales (r = 0.76) correlate most strongly with the PCS score, and are the most valid physical health measures; Mental health (r = 0.87), role-emotional (r = 0.78) and social functioning (r = 0.67) correlate most strongly with the MCS score and are the most valid mental measures | Median item-scale correlation (corrected for overlap) for each of the 8 scales ranged from 0.63 (general health) to 0.79 (mental health); all items except for general health (r = 0.38) exceeded the 0.40 standard for item-internal consistency; overall trends in item-internal consistency were replicated across patient subgroups; Median-item scale correlations for the 8 scales remained high across subgroups ranging from: 0.39 to 0.80 | Each scale exceeded the minimum reliability standard of 0.70 for group comparisons; most reliability estimates for physical and mental summary scores exceed 0.80, and 0.90 for the PCS and MCS; Reliability ranged from 0.78 (general health) to 0.93 (physical functioning); Range for subgroups was 0.65 to 0.94 | Mental health scale and MCS are useful in screening for psychiatric disorders (e.g. with a cut off score of 42, MCS has a sensitivity of 74% and a specificity of 81% to detect depressive disorder); 3 physical scales are the most responsive to benefits of knee and hip replacement, and heart valve surgery; 3 mental health scales are the most responsive in comparisons of pt before and after recovery from depression, change in severity of depression and treatment for depression
Low vision-related HRQL assessment tools
VFQ–25^63,73^ | VFQ–51—visually impaired persons with diverse eye conditions (N = 598 total; N with DR = 123; N pt included in test-retest reliability analysis = 96); VFQ–25—visual impaired persons with diverse eye conditions (N=859 [597 pt from previous study]; N with DR = 181) | VFQ–51—high correlations between VFQ scales and the VF–14 and ADVS: activity-oriented scales (near, distance vision and driving scale) and other vision-targeted scales: r = 0.9 to 0.6, p = 0.01; general vision ratings : r = 0.7, p < 0.001; mental distress ratings: r = 0.7, p = 0.001; significant correlation for peripheral and color vision with Visual Activities Questionnaire; poor correlation with most SF–36 scales, highest correlation between SF–36 mental component and VFQ-51 mental distress ratings: r = 0.4, p=0.001; correlations between VFQ-51 and ETDRS VA were moderate for scales that reflected the difficulty pt had with visual activities. VFQ–25—Correlations between the VFQ–25 subscales and VFQ-51 counterparts >0.90; correlations between responses on VFQ–25 and ETDRS visual acuity were in the range of 0.65 to 0.70 for subscales that reflected the degree of difficulty with visual activities related to general vision, near vision and distance vision; remaining subscales showed lower correlations ranging from 0.39 to 0.69 with the exception of the ocular pain subscale (lowest) between 0.06 to 0.11 | VFQ–51—Cronbach's α for subscales range from 0.66 to 0.94; 86% of internal consistency estimates ≥ 0.7; VFQ–25—Subscale ranges from 0.71 to 0.85; among persons with eye disease, all 8 multi-item subscales had an internal consistency ≥0.70 | VFQ–51—ICC for the 11 subscales range from 0.68 to 0.91 | Scale scores improve with intervention; greater improvement in visual function is associated with greater improvement in HRQL; Correlations between responses on the VFQ-51 and ETDRS visual acuity were moderate for scales that reflect the degree of difficulty that a person has with common visual activities; Correlations between each of the scales and visual acuity in the better and worse eyes were similar in magnitude
VF–14^66,74^ | Patients undergoing cataract surgery (N = 766); 522 pt of original population used to test responsiveness (had not received second surgery by 4 mo followup); 383 pt of original population used to test reproducibility (had not received second surgery by 12 mo followup) | Criterion validity assessed by examining the correlation between VF–14 scores and other measures of vision included visual acuity and global self-rating of the overall difficulty and satisfaction patients had with their vision; VF–14 with pt self-reported trouble with vision (r = -0.45) and overall satisfaction with vision (r = 0.34) higher than correlations with other vision measures; correlation between VF–14 score and visual acuity was strongest in the better eye (r = 0.27); VF–14 moderately correlated with SIP score (r = -0.39); and strongly correlated with VR-SIP score (r = -0.57) | Cronbach's α for total scale = 0.85; Cronbach's α for subscales ranged from 0.32 to 0.61 | In pt whose 12 mo followup BCVA in each eye remained within 1 Snellen line of 4 mo followup value (n = 249) (mean VF–14 scores at 12 mo 1.5 points lower than 4 mo scores): ICC = 0.57; In pt with no difference between 12 mo and 4 mo followup BCVA (n = 96) (mean difference between 4 and 12 mo followup VF–14 scores = 1.7 points; p<0.05): ICC = 0.71; In pt with no complications (n = 47) (no significant difference in mean 4 and 12 mo followup scores): ICC = 0.76; Pt who had identical answers to 2 global questions r/t trouble and satisfaction with vision (n = 119) (mean VF–14 scores at 12 mo followup 1.1 points lower than 4 mo followup score; p<0.05): ICC = 0.79; After adjusting for pt who scored 100 points on VF–14 at both 4 and 12 mo: ICCs = 0.50 to 0.73 | Pts who underwent cataract removal in one eye (up to 4 mo followup) (n = 522): effect size 1.02 for VF–14, -0.26 for SIP; Pt whose VA in operated eye improved by ≥ 2 Snellen lines: effect size 1.07 (VF–14), -0.29 (SIP)—results did not differ when patients stratified by baseline VA; Pt whose functional status improved at 4 mo followup (n = 510): effect size 1.06 (VF–14), -0.27 (SIP); Pt who reported an improved rating of amount of trouble with vision at 4 mo followup (n = 438): effect size: 1.17 (VF–14), -0.28 (SIP); Pt who reported improved rating of satisfaction with vision at 4 mo followup (n = 470): effect size: 1.14 (VF–14), -0.30 (SIP)
Diabetes-related HRQL assessment tools
DTSQ75 | Pt with diabetes mellitus (n = 286); divided into 3 groups: CSII: continuous subcutaneous insulin infusion; ICT: intensified conventional therapy; CT: conventional therapy | Evidence of construct validity demonstrated in populations with diabetes mellitus (not DR) by relationships between treatment satisfaction and: being less overweight (r = 0.19; p<0.05); having better glycemic control (r = -0.28; p<0.001) and being optimistic about recent diabetes control (r = 0.56; p<0.001) | Cronbach's α for total scale = 0.76; When item: how many hypoglycemic experiences have you experienced recent was removed, α = 0.79 for total scale | No data | Low score indicates that level of satisfaction has increased during the year; if no change occurred, a score of 21 would be obtained; Significantly different scores on the 3 subscales obtained between CSII, ICT and CT: F = 30.4; df 2, 123; p<0.001; Significant interaction between CSII, ICT, and CT, and magnitude of subscale score: F = 4.81; df 4, 246; p<0.001)
Diabetic retinopathy-related HRQL assessment tools
RetDQoL70 | Patients with DR (N = 207) | Predefined hypotheses were tested: Greater visual impairment, advanced stages of DR, & additional impact of DME will lead to more negative impact on QoL: confirmed; Significant correlation with clinical variables for overview items I (present QoL) and II (retinopathy-specific QoL), and the AWI of domain-specific items: confirmed with exception of stage of DR and item I ; Significant correlations between AWI and overview items I and II, with the strongest positive relationship between AWI and overview item II: confirmed; Small significant correlations with subscales of SF–12: confirmed; Small significant correlation with tx satisfaction as measured by RetTSQ: confirmed; No significant correlations with sociodemographic variables: not confirmed for item I (living alone, employment, age, sex); confirmed for item II | Cronbach's α weighted impact scores for all domains = 0.958; Cronbach's α for unweighted impact scores and the importance ratings = 0.96, 0.84, respectively | No data | No data
RetTSQ71 | Patients with DR (N = 207) | Predefined hypotheses were tested: Greater visual impairment, advanced stages of DR, & additional impact of DME are associated with less tx satisfaction: confirmed; Moderate significant correlations with subscales of SF–12: confirmed; Positive correlations between tx satisfaction and QOL scores on RetDQoL: confirmed; No significant correlations with sociodemographic variables: confirmed | Cronbach's α of total scale = 0.90; Cronbach's α for both of the subscales = 0.85 | No data | No data

ADVS = Activities of Daily Vision Scale; BCVA = best corrected visual acuity; DR = diabetic retinopathy; dx = diagnosis; DTSQ = Diabetes Treatment Satisfaction Questionnaire; ETDRS = Early Treatment of Diabetic Retinopathy Study; HRQL = health-related quality of life; ICC = interclass correlation coefficient; MCS = mental component summary; mo = month; MOS = Medical Outcomes Study; PCS = physical component summary; pt = patient; QoL = quality of life; RetDQoL = Diabetic Retinopathy Dependent Quality of Life; RetTSQ = Diabetic Retinopathy Treatment Satisfaction Questionnaire; r/t = related to; SES = socioeconomic status; SIP = sickness impact profile; tx = treatment; US = United States; U.K. = United Kingdom; VA = Visual Acuity; VF = visual function; VFQ = National Eye Institute Visual Function Questionnaire

Table 2 Rating of the psychometric properties health-related quality of life assessment tools used in studies of treatment of diabetic retinopathy

Measure | Content validity | Construct validity | Internal consistency | Test re-test reliability | Measurement error | Responsiveness | Interpretability
SF–36 | + | + | + | + | + | + | +
VFQ–25 | + | + | + | + | 0 | ? | ?
VF–14 | ? | + | + | ? | 0 | ? | 0
DTSQ | + | + | + | + | + | + | 0
RetDQoL | + | + | + | 0 | 0 | 0 | 0
RetTSQ | + | + | + | 0 | 0 | 0 | 0

Method or result was rated as: += high quality; ?: indeterminate; -: low quality; 0: no data available

### Generic Assessment Tools

#### Medical Outcomes Study 36–Item Short Form Health Survey (SF–36)

The SF–36 is a 36 item questionnaire designed for use as a generic indicator of health status in clinical use, research, population surveys, and evaluative studies of health policy.56 It incorporates physical, social, and mental concepts of both positive and negative aspects health. A higher score on the SF–36 represents better health. It has been used for evaluation in a variety of conditions and for comparisons of different populations including the general public.57

Reliability and validity of the SF–36 have been examined in both healthy and patient populations. Construct validity is good, and when compared with other health instruments (Sickness Impact Profile, Quality of Well-being Scale, Nottingham Health Profile), the SF–36 was more sensitive to change of community dwelling elderly persons, elderly patients, and patients with joint replacements.58-60 However, the study by Matza49 found that the SF–36 was unable to differentiate changes in visual acuity after treatment for DR, especially when compared with the VFQ–25.

Advantages of the SF–36 as compared to other generic instruments are its brevity and comprehensiveness. Limitations have been identified with validity pertaining to chronic disabilities, the severely ill, and the elderly. Some experts question the responsiveness of scores to changes in health status with certain populations, particularly: potential floor effects in the severely ill56 and ceiling effects in healthy elderly people residing in the community.60 Finally, the appropriateness of the SF–36 in the elderly is unclear61 due to evidence that shows high percentages of missing data in this population.59,62 Hayes and colleagues reported missing data in 70 percent of 122 respondents who were 75 years of age and older; however, they hypothesized this was likely related to visual or writing problems.62

### Low-Vision Related Assessment Tools

#### National Eye Institute Visual Function Questionnaire-25-item version (VFQ–25)

The VFQ–25 is a reduced version of the National Eye Institute's 51-item VFQ developed to elicit patient perceptions of their visual impairment and its relation to HRQL. The VFQ–25 includes 1 general health item in addition to 11 visual subscale scores of: general vision, ocular pain, near vision, distance vision, social function, mental health, role limitations, dependency, driving, color vision, and peripheral vision. A high score on the VFQ–25 indicates better visual function and HRQL.63 The reliability and validity of the VFQ–25 has been demonstrated in a variety of eye conditions including: cataracts, age-related macular degeneration, DR, primary open-angle glaucoma, and cytomegalovirus retinitis.63 Furthermore, a strong association between the VFQ–25 and visual acuity has been demonstrated, independent of the degree of retinopathy.64 A Japanese version of the VFQ–25 was used in the studies by Okamoto et al.41,43 and Emi et al.,45,46 and has been shown to be reliable and valid in the Japanese population.65

#### Visual Function–14 (VF–14)

The VF–14 asks patients to assess their ability to perform 14 everyday activities that can be affected by cataracts. There are 18 items related to visual acuity including: reading, recognizing people, seeing steps, stairs or curbs, doing fine handwork, writing checks or filling out forms, playing games, taking part in sports, cooking, watching television, and driving. A higher score on the VF–14 indicates that the patient is better able to complete the everyday activities included in the questionnaire.66 Boisjoly50 found that in a variety of eye conditions, the VF–14 was more strongly correlated with changes in patients' self-reported visual trouble and satisfaction with vision than with changes in visual acuity and general outcome measures.

### Diabetes-Related HRQL Assessment Tools

#### Diabetes Treatment Satisfaction Questionnaire (DTSQ)

The DTSQ measures patients' satisfaction with the treatment they receive for their diabetes. It has been designed for use only with persons with either type 1 or type 2 diabetes mellitus and has not been validated for use in the narrower population of patients with DR. Six items on the questionnaire are combined to provide a measure of treatment satisfaction; the remaining two items evaluate the perceived frequency of hyperglycemia and hypoglycemia. A high score on the DTSQ indicates the patient has a high level of satisfaction with their treatment.67 The DTSQ can effectively measure psychological outcomes related to diabetes treatment and has demonstrated sensitivity to changes in patient satisfaction related to changes in diabetic interventions.68

### Diabetic Retinopathy Related HRQL Assessment Tools

#### Diabetic Retinopathy Dependent Quality of Life (RetDQoL)

The RetDQoL is a recently developed tool designed to evaluate the QOL of patients diagnosed with DR and is modeled on the Audit of Diabetes-Dependent QoL.69 The questionnaire begins with two broad questions related to present quality of life and what the patient's perceived QOL would be if they did not have diabetic eye problems. The remaining 24 items are specific questions related to aspects of QOL. Each item is split into two parts: part “a” asks the patient to evaluate the impact of the domain on their QOL; part “b” asks the patient to rank how important each domain is in their life. The RetDQoL has demonstrated high internal consistency and good construct validity.70 The RetDQoL has not yet been used in clinical trials investigating the impact of an intervention for DR.

#### Diabetic Retinopathy Treatment Satisfaction Questionnaire (RetTSQ)

The RetTSQ is a recently developed tool designed to evaluate patients' satisfaction with the treatment they receive for their DR. The DTSQ was used as a model for the development of this questionnaire. The RetTSQ is comprised of 13 items relating to patient satisfaction with different areas of treatment for DR. The 13 items are split into two subscales: one used to evaluate positive aspects of treatment, and the other to evaluate negative aspects. A high score on the RetTSQ indicates a high level of satisfaction with treatment. The internal consistency of the RetTSQ has been demonstrated to be high, and construct validity to be good. The RetTSQ has not been used in any clinical trials to evaluate the impact of an intervention for DR.71

## Key Questions 2 and 3 What is the evidence that HRQL is improved by any intervention; and what is the relationship between HRQL and any relevant variables?

### Description of Included Studies

We identified two RCTs and seven observational studies that addressed Key Questions 2 and 3. The population and study characteristics are summarized in Table 3. Additional population and study characteristics are available in Appendix F.

Table 3 Study characteristics and outcomes for studies reporting the impact of interventions for diabetic retinopathy on HRQL

Author Year Study design Country | Intervention HRQL measure Followup | Participants | Visual acuity outcomes | HRQL outcomes
Anti-VEGF
Mitchell 2011^47^ RCT Multicenter (73 centers in Australia, Canada, Europe, Turkey) | G1—ranibizumab 0.5 mg + sham laser G2—ranibizumab 0.5 mg + laser G3—laser + sham injection VFQ-25 3 mo, 12 mo | G1 = 116 G2 = 118 G3 = 111 DME = 345 (100%) | Median change in BCVA from baseline to 12 mo: G1 = 6.1±6.43 G2 = 5.9±7.92 G3 = 0.8±8.59 Median change in BCVA from baseline to 12 mo: G1 = 6.1 (-10.9–25.2) G2 = 6.0 (-26.7–27.6) G3 = 1.3 (-37.8–26.8) 95% CI for the mean change: G1 = 4.9, 7.3 G2 = 4.4, 7.3 G3 = -0.8, 2.4 | VFQ-25, composite score at 12 mo G1—baseline: NR; improvement: 5.0 (p=0.014 compared to G3) G2—baseline: NR; improvement: 5.4 (p=0.004 compared to G3)) G3—baseline: NR; improvement: 0.6 (NR) Other domains: G1—significant improvement for general vision, near vision activities, distance activities; other domains: NR G2— significant improvement for general vision, near vision activities, distance activities; other domains: NR G3—baseline: NR; no significant change from baseline
Sultan 2011^42^ RCT Multicenter (60 centers in Australia, Europe, India, North America, South America) | G1—pegaptanib 0.3 mg G2—sham injection VFQ–25 baseline, 18, 54 & 102 wk | G1 = 133 G2 = 127 DME = 260 (100%) | % improvement of ≥10 letters from baseline at 54 wk: G1 = 43/133 (36.8%) G2 = 25/127 (19.7%) Odds ratio (95% CI) = 2.38 (1.32, 4.30); p=0.0047 % improvement of ≥10 letters from baseline at 102 wk G1 = 41/107 (38.3%) G2 = 30/100 (30%) Odds ratio (95% CI) = 1.57 (0.83, 2.97); p=0.1729 | VFQ-25, composite score at 54 wk: G1—70.4; improvement 4.5 G2—69.2; improvement 1.3 Between group differences—2.92; range -0.32 to 6.16 (p = 0.077) VFQ-25, composite score at 102 wk (n = 207): G1—69.8; improvement 4.6 G2—66.2; improvement 0.1 Between group differences—4.47; range - 0.26 to 8.68 (p = 0.038) Other domains: 54 wk: G1 vs. G2 had significantly more improvement for near vision activities, distance activities, social functioning; no difference for other domains 102 wk: G1 vs. G2 had significantly more improvement for distance activities, social functioning, mental health; no difference for other domains
Laser photocoagulation
Tranos 2004^48^ Before-after United Kingdom | Laser photocoagulation VFQ–51 3 mo | DME = 55 (100%) Mild NPDR = 13 Moderate NPDR = 32 Severe NPDR = 10 | Binocular vision—baseline: 48.7±6.7 Distance vision—baseline: 42.7±8.4 letters; improvement: 2.2±6.2 Near vision—baseline: 56.4±9.1 letters; improvement: 2.1±5.0 | Composite score—baseline: 77.9±17.6; improvement: 4.9±8.9 (p<0.001); Subscales—statistically significant improvement on 8 of 11 vision-related domains
Mozaffarieh 2005b Before-after Austria | Laser photocoagulation DTSQ 9 mo | Total = 105 PDR = 56 (53%) DME = 49 (47%) | 24.7% reported improvement in visual acuity; 71.4% were unchanged; 3.8% were worse No difference in improvement between patients with PDR or DME | Mean± SD = 27.9±5.2 (maximum possible score = 36)
Vitrectomy
Emi 2008^45^ Before-after Japan | Vitrectomy VFQ–25 (Japanese version) 6 mo | DR = 87 (total) G1—vitreous hemorrhage = 41 G2—DME = 28 G3—fibrovascular membrane = 18 | G1—improved: 35; unchanged: 4; worse: 2 G2—improved: 9; unchanged: 16; worse: 3 G3—improved: 13; unchanged: 3; worse: 2 | G1—statistically significant improvement on 10 of 12 subscales G2—no statistically significant change from baseline on any subscales G3—only the general vision subscale had a statistically significant improvement from baseline
Okamoto 2010^41^ Prospective cohort Japan | Pars plana vitrectomy VFQ–25 (Japanese version) 3 mo | G1—PDR = 99 G2—DME = 38 G3—normal controls = 100 Note: this is part of a larger study (n = 399) of patients with vitreoretinal disorders—retinal vein occlusion (32), macular hole (42), epiretinal membrane (33), retinal detachment (55) | logMAR G1—baseline: 1.37±0.75; 3 mo: 0.53±0.62 (p < 0.0001) G2—baseline = 0.76±0.49; 3 mo: 0.55±0.51 (p < 0.01) Contrast sensitivity G1—baseline: 5.4±7.2; 3 mo: 14.0±7.9 (p < 0.0001) G2—baseline 9.2±6.5; 3 mo: 12.7±7.1 (p < 0.0001) | G1—baseline: 52.8±19.0; 3 mo: 63.6±17.5 (p <0.001); Subscales—statistically significant improvement on 9/11 vision-related domains G2—baseline: 53.0±20.5; 3 mo: 59.0±21.0 (p = 0.84); Subscales—statistically significant improvement on 4/11 vision-related domains G3—85.0±9.1
Vitrectomy and panretinal photocoagulation
Emi 2009^46^ Prospective cohort Japan | G1—vitrectomy G2—panretinal photocoagulation G3—no treatment VFQ–25 (Japanese version) 1 yr | G1 = 136 G2 = 60 G3 = 131 | logMAR—right eye G1—baseline: 0.21; 1 yr: 0.46 (p < 0.001) G2—baseline: 0.64; 1 yr: 0.52 (p = 0.272) G3—baseline: 1.09; 1 yr: 1.06 (p = 0.294) logMAR—left eye G1—baseline: 0.19; 1 yr: 0.38 (p < 0.001) G2—baseline: 0.61; 1 yr: 0.56 (p = 0.081) G3—baseline: 1.10; 1 yr: 1.09 (p = 0.704) | Composite score G1—baseline: 67.4±17.3; 1 yr: 75.4±17.5 (p<0.001) G2—baseline: 80.7±15.7; 1 yr: 77.6±19.1 (p=0.113) G3—baseline: 91.3±7.8; 1 yr: 92.2±7.8 (p=0.169)
Phacoemulsification cataract surgery
Mozaffarieh 2005a53 Prospective cohort Austria | Phacoemulsification cataract surgery VF–14 3 mo | Cataracts = 67 (total) G1—no DR = 17 G2—mild NPDR = 19 G3—moderate/severe NPDR = 16 G4—PDR = 15 | logMAR (range) G1—baseline: 0.62 (0.30–1.30); improvement 0.55 (0.30–1.15) G2—baseline: 0.60 (0.30–1.30); improvement 0.50 (0.30–1.08) G3—baseline: 0.67 (0.30–1.30); improvement 0.26 (0.15–0.48) G4—baseline: 0.71 (0.40–1.30); improvement 0.15 (-0.70–0.60) | G1—baseline: 52.21 (32.14–78.57); improvement 42.33 (21.43–60.71) G2—baseline: 55.92 (30.36–85.71); improvement 36.00 (12.50–58.93) G3—baseline: 46.65 (30.36–64.29); improvement 9.26 (1.79–25.00) G4—baseline: 40.12 (25.00–67.86); improvement 5.00 (-25.00–25.00)
Mozaffarieh 2009^51^ Prospective cohort Austria | Phacoemulsification cataract surgery G1—first-eye surgery G2—both eyes VF–14 12 mo | Cataracts = 89 (total) No DR = 23 Mild NPDR = 23 Moderate NPDR = 22 PDR = 21 | G1 & G2—patients with no or mild NPDR had greater improvement in visual acuity | G1 baseline: no DR: 59.3±12.4; mild 39.3±5.2; severe 40.9±8.6; PDR 35.3±4.4 6 mo: no DR: 96.8±2.0; mild 86.5±13.6; severe 48.8±6.7; PDR 37.9±14.0 12 mo: no DR: 79.5±5.5; mild 72.2±8.3; severe 46.1±10.7; PDR 39.9±9.0 G2 baseline: no DR 46.8±8.7; mild 63.4±16.3; severe 54.6±8.8; PDR 50.6±11.4 6 mo: no DR: 93.0±4.3; mild 94.6±2.5; severe 60.9±6.6; PDR 53.0±10.9 12 mo: no DR: 95.3±1.9; mild 95.3±2.2; severe 47.8±16.0; PDR 47.6±15.0

95% CI = 95 percent confidence interval; BCVA = best corrected visual acuity; DR = diabetic retinopathy; DTSQ = Diabetes Treatment Satisfaction Questionnaire; DME = diabetic macular edema; mg = milligram; mo = month; NPDR = nonproliferative diabetic retinopathy; PDR = proliferative diabetic retinopathy; VF–14 = Visual Function–14; VFQ = National Eye Institute Visual Function Questionnaire; wk = week; yr = year

The two RCTs42,47 were multicenter trials that recruited patients in Australia, North and South America, Europe, India, and Turkey. The trials examined two anti-VEGF treatments in patients with DME. The RESTORE study47 was a three-arm double-masked RCT (n = 345) that compared ranibizumab monotherapy versus ranibizumab plus laser versus laser. The Macugen 1013 study42 (n = 260) was a double-masked RCT comparing pegaptanib sodium versus sham.

For the observational studies, the interventions included laser photocoagulation,48,54 vitrectomy, 41,45,46 panretinal photocoagulation,46 and phacoemulsification cataract surgery for diabetic patients with cataracts.51,53 Sample sizes ranged from 55 to 345 (IQR: 77 – 293.5). As a post hoc analysis, we examined the subgroup of patients with DME. Six studies41,42,45,47,48,54 reported some results for those with DME. Two studies51,53 included patients with DME, but did not report separate results. Patients with DME represented less than five percent of the study sample in these studies. One study46 did not report whether patients with DME were included in their study.

### Methodological Quality

Both RCTs were assessed as “unclear” risk of bias. The primary concern for both trials was incomplete outcome data and the use of the last observation carried forward approach for missing data. For the Macugen 1013 study,42 all other domains were assessed as low risk of bias. For the RESTORE study,47 the domains for allocation concealment, blinding of HRQL assessment, and baseline balance for HRQL were assessed as unclear; the remaining domains were low risk of bias. Both trials received industry funding.

There were four cohort studies41,46,51,53 and three before-after studies.45,48,54 All data were collected prospectively. The methodological quality of the cohort studies was assessed as good for one51 (7/8 stars), moderate for one53 (6/8 stars), and low for two (3 or 4 of 8 stars). Two studies53,54 enrolled patients that were rated to be truly or somewhat representative of average patients in the community, and the nonexposed cohort was drawn from the same community. For the remaining two studies, there was no description of the derivation of the cohort. All studies ascertained the exposure status from a secure source, most commonly from patient records. Two studies53,54 controlled for potential confounders through multivariate analyses. All studies used a validated tool for outcome assessment. Two studies46,51 had a followup duration of at least 6 months. For all studies, the rate of followup was either complete or considered unlikely to introduce bias.

The methodological quality of the before-after studies was assessed as good for one54 (5/5 stars) and moderate for two45,48 (4/5 stars). Two studies45,54 enrolled patients that were rated to be truly or somewhat representative of average patients in the community. All studies ascertained the exposure status from a secure source, most commonly from patient records. All used a validated tool for outcome assessment. Two studies45,54 had a followup duration of at least 6 months. For all three studies, the rate of followup was either complete or unlikely to introduce bias.

Overall this collection of observational studies is at high risk of bias due to weak study designs (before-after and cohort studies).

### Results

The results are grouped by the type of intervention (e.g., anti-VEGF, laser photocoagulation). Three observational studies41,48,54 conducted multivariate analyses to identify variables associated with HRQL outcomes; these results are presented with their respective studies. Table 4 summarizes the outcomes.

Table 4 Strength of evidence for health-related quality of life outcomes

Design # studies (sample size) | Risk of Bias | Consistency | Directness | Precision | Strength of evidence
Anti-VEGF
2 RCTs (n = 605) | Medium | Inconsistent (at 1 yr) | Direct | Not pooled | Low
Laser photocoagulation
2 before-after studies (n = 160) | High | Unknown (single study) | Direct | Not pooled | Insufficient
Vitrectomy
1 cohort study (n = 237) 1 before-after study (n = 87) | High | Consistent | Direct | Not pooled | Insufficient
Vitrectomy and panretinal photocoagulation
1 cohort study (n = 327) | High | Unknown (single study) | Direct | Not pooled | Insufficient
Phacoemulsification cataract surgery
2 cohort studies (n = 156) | Medium | Consistent | Direct | Not pooled | Insufficient

#### Anti-VEGF

From September 2005 to November 2009, the Macugen 1013 Study group42 conducted a multicenter trial that investigated the efficacy of pegaptanib sodium versus sham injections. All patients were diagnosed with DME. Patients were randomized to receive 0.3 mg of pegaptanib sodium (n=133) or a sham treatment designed to mimic the intravitreal injection process (n=127). The primary efficacy endpoint was the number of patients who gained 10 letters or more on visual acuity compared to baseline. At 54 weeks after baseline 49 of 133 (36.8 percent) patients treated with pegaptanib had achieved an improvement of 10 or more letters, compared with 25 of 127 (19.7 percent) in the sham injection group. The odds ratio was 2.38 (95% CI, 1.32 to 4.30, p=0.0047). Additionally, patients who received pegaptanib reported statistically (p<0.05) and clinically significant (>5 point difference) improvements on the VFQ–25 at 54 weeks on the near vision, distant vision, and social functioning subscales. The change in composite score was not statistically significant. At 102 weeks after baseline, patients who received pegaptanib reported statistically (p<0.05) and clinically significant (>5 point difference) improvements on the composite score, and the distance vision, social functioning and mental health subscores compared with patients treated with a sham injection.

The RESTORE Study group47 conducted a multicenter trial that investigated the efficacy of ranibizumab with and without laser treatment. All patients were diagnosed with DME. Patients were randomized to recieve 0.5 mg of ranibizumab plus sham laser treatment (n=116), 0.5 mg of ranibizumab plus laser treatment (n=118), and sham treatment plus laser treatment (n=111). The mean change in best corrected visual acuity (BCVA) from baseline to 12 months was the primary outcome. For patients treated with ranibizumab alone, 22.6 percent achieved a BCVA letter score of 15 or more, and 53 percent attained a BCVA letter score level more than 73 (20/40 Snellen equivalent); whereas 22.9 percent and 44.9 percent, respectively achieved those gains among the patients treated with ranibizumab plus laser therapy. Of patients who received laser treatment, 8.2 percent improved 15 or more letters on BCVA, and 23.6 percent reached a BVCA letter score more than 73. Scores on the VFQ–25 were significantly improved from baseline to 12 months for patients treated with ranibizumab alone and patients treated with ranibizumab in combination with laser compared with patients with laser treatment only. For the ranibizumab monotherapy group the composite score increased by 5.0 points compared with an increase of 0.6 for the laser treatment group (p=0.014). Similarly for the ranibizumab plus laser treatment group, the composite score increased by 5.4 points (p=0.004). Furthermore, at 12 months ratings of good to excellent vision were reported by 46 percent of patients treated with ranibizumab alone and 50 percent of those treated with ranibizumab plus laser treatment. This compares with 22 percent of patients who received only laser treatment. The proportion of patients reporting excellent to good vision at baseline were similar across the three groups—21 percent (ranibizumab), 23 percent (ranibizumab plus laser treatment), and 24 percent (laser only).

#### Laser photocoagulation

Tranos et al.48 conducted a prospective study that followed 55 patients with DME. Best corrected visual acuity for distance vision and near vision were recorded as the number of letters read correctly on Early Treatment of Diabetic Retinopathy Study (ETDRS) charts at 4 meters and 40 centimeters, respectively. The mean baseline visual acuity was 42.7±8.4 (distance) and 56.4±9.1 (near). Patients completed the VFQ–51 prior to and 3 months following the last session of laser treatment. At the end of the followup period, DME had resolved in 46 (84 percent) patients, although improvement in visual acuity was small. Based on the VFQ–51, laser treatment resulted in an improvement in patients' perceived functional status and QOL. The composite score and the subscale scores associated with general vision, near vision, distance vision, vision-specific mental health, expectations for visual function, and dependency due to vision were significantly improved following laser treatment.

Multivariate models showed that improvement of the VFQ–51composite score was associated with age less than 65 years (p = 0.04), number of laser spots (indicating more extensive treatment; p = 0.02), and worse vision-related QOL prior to laser treatment (p = 0.03). There was no statistically significant association between change in the composite score and stage of DR or duration of diabetes.

From June 2002 to March 2004, Mozaffarieh et al.54 followed 105 patients undergoing first photocoagulation treatment for DME (n = 49) or proliferative diabetic retinopathy (PDR) (n = 56). Patients had laser treatments at 4 and 9 months, and then a final examination 12 months after the initial laser treatment. Best-corrected visual acuity was recorded using a Snellen chart, and visual acuity improvement was defined as the difference between the pre- and post-treatment logarithm of minimal angle of resolution (logMAR) acuity. All patients completed the DTSQ after their initial and final (9 month) laser treatments. Nine months after initial photocoagulation treatment 24.7 percent of all patients reported improvement in visual acuity. Vision remained the same in 71.4 percent and worse in 3.8 percent. These values remained constant 12 months after initial treatment for all but one patient whose vision deteriorated further. There was no statistically significant difference in vision improvement between patients with DME and PDR. Based on a maximum possible score of 36, satisfaction after the final (9 month) laser treatment was high (mean score = 27.9±5.2), with 42.8 percent scoring 31 or higher. Results of the DTSQ were not reported separately for the two groups of patients.

The Spearman correlation between treatment satisfaction and the patients' visual acuity after laser treatment for patients with DME and PDR was modest (r = 0.28–0.33, p>0.2). Satisfaction was associated with age, with older patients being more satisfied than younger patients (Spearman coefficient r = 0.41–0.56, p<0.001).

#### Vitrectomy

In a prospective study, Okamoto et al.41 investigated vision-related QOL in 299 patients undergoing pars plana vitrectomy for various vitreoretinal disorders. The authors reported results separately for patients with PDR (n = 99) and DME (n = 38). The logMAR best corrected visual acuity and letter contrast sensitivity were obtained preoperatively and at 3 months postoperatively. All patients completed the VFQ–25 (Japanese version) before and 3 months after surgery. One hundred healthy volunteers who served as normal control subjects also completed the VFQ–25. Vitrectomy significantly improved visual acuity and contrast sensitivity in both patient groups. For patients with PDR, the composite VFQ–25 score and most subscale scores improved significantly following vitrectomy. The composite score gained 10.8±18.3 points. For those with DME, the change in the composite score was 6.0±20.8, but was not statistically significant. The only vision related subscales that showed statistically significant improvements for patients with DME were general vision, near activities, mental health, and peripheral vision. The composite score for the normal controls was 85.0±9.1, which is statistically significantly higher than the preoperative and postoperative composite scores in patients with PDR and DME.

Multiple regression analysis showed that improvement in contrast sensitivity was significantly correlated with changes in the VFQ–25 composite score for patients with PDR and DME. There was no significant correlation between changes in the VFQ–25 and postoperative visual acuity.

Emi et al.45 followed 87 patients with DR. Of these, 41 (47 percent) had vitreous hemorrhage, 28 (32 percent) had DME, and 18 (21 percent) had fibrovascular membrane. All patients completed the VFQ–25 (Japanese version) 1 month before and 6 months after vitrectomy. At 6 months, 35 (85 percent) patients with vitreous hemorrhage reported that their visual acuity had improved; the remaining patients reported visual acuity as unchanged (n = 4) or worse (n = 2). For patients with DME and fibrovascular membrane, 9 (32 percent) and 13 (72 percent) reported improved visual acuity, respectively. For all patients, the mean VFQ–25 following vitrectomy increased in all 12 subscales; however, the changes were not statistically significant. Only the subgroup of patients with vitreous hemorrhage reported statistically significant improvements for 10 of the 12 subscales of the VFQ–25. For the subgroup of patients with fibrovascular membrane, the only subscale that had a statistically significant change from baseline was general vision.

#### Vitrectomy and panretinal photocoagulation

In a second study by Emi et al.,46 327 patients with DR were followed for 1 year. Of these, 136 (42 percent) underwent vitrectomy, 60 (18 percent) received panretinal photocoagulation, and 131 (40 percent) did not have any treatment and served as a comparison group. All patients completed the VFQ–25 (Japanese version) at the time of entry into the study and 1 year later. Visual acuity was reported as the logMAR score for the right and the left eyes. For the vitrectomy group, the VFQ–25 composite score improved by eight points and the change was statistically significant. Changes in the composite scores for the comparison group and the photocoagulation group were not statistically significant. At baseline, the VFQ–25 composite score for the vitrectomy group was significantly lower than that of either of the other groups; at 1 year followup, there was no statistically significant difference between the vitrectomy and the photocoagulation groups.

#### Phacoemulsification

From May 2001 to May 2003, Mozaffarieh et al.53 prospectively evaluated visual outcomes and visual function after first-eye phacoemulsification cataract surgery. A total of 67 patients with different stages of DR were included: 17 patients had no apparent DR (group 1), 19 had mild nonproliferative diabetic retinopathy (NPDR) (group 2), 16 had moderate/severe NPDR (group 3), and 15 had proliferative diabetic retinopathy (PDR) (group 4). Patients were followed for 3 months after surgery. All patients completed the VF–14 prior to and 3 months after surgery. Three months postoperatively, 94.2 percent of patients reported improved visual acuity and 92.5 percent reported improvements in visual function. Improvements in both visual acuity and visual function decreased as the baseline level of retinopathy increased. Patients with no DR or mild retinopathy (groups 1 and 2) demonstrated significantly greater improvements in visual acuity and visual function compared with patients with more advanced DR (group 3 and 4).

From May 2000 to March 2004, Mozaffarieh et al.51 followed 89 diabetic patients with bilateral cataracts. Of these, 66 had DR (mild NPDR: 35 percent, moderate/severe NPDR: 33 percent, PDR: 32 percent). Forty-one patients had surgery on one eye (group 1), and 48 had subsequent surgery on the second eye (group 2) at least 6 months later. Patients completed the VF–14 prior to surgery and 1, 3, 6, 8, and 12 months postoperatively. Patients with PDR had the lowest VF–14 scores at baseline and improved marginally over the study period regardless of whether they had surgery on one or both eyes (improvement of 2.6±10.8 points and 2.4±5.2 at 6 months, and 4.6±7.3 and -2.98±7.4 (decrease) at 12 months, respectively). A similar pattern was seen for patients with moderate/severe NPDR with an increase of 7.8±8.0 points and 6.2±5.6 at 6 months and 5.2±8.2 and -6.85±15.3 (decrease) at 12 months, respectively. For patients with no or mild NPDR, maximum VF–14 scores at 12 months followup were significantly higher than patients with more severe DR.

The impact of first-eye cataract surgery on QOL was evident in patients with no or mild DR with the highest VF–14 scores being achieved by 91.3 percent of patients in the first month. In contrast, for those with more severe DR 79.1 percent achieved the highest VF–14 score after 3 months.

In patients with no or mild DR who underwent second-eye surgery the improved functional status achieved after first surgery was sustained. For those who did not have second-eye surgery VF–14 scores decreased after 8 and 12 months. For those with more advanced levels of DR, there were no significant gains after second eye surgery at 12 months.

### Summary of Findings

Anti-VEGF. Two RCTs provided data. In one RCT, 133 patients received 0.3 mg of pegaptanib sodium versus 127 patients who received a sham injection. All patients were diagnosed with DME. At 54 weeks there was no statistically significant difference between groups in the composite score on the VFQ–25. At 102 weeks, patients receiving pegaptanib sodium reported statistically significant improvements in the composite score. The second RCT was a three-arm trial comparing 0.5 mg of ranibizumab plus sham laser treatment (n=116), 0.5 mg of ranibizumab plus laser treatment (n=118), and sham treatment plus laser treatment (n=111). All patients were diagnosed with DME. The composite score on the VFQ–25 was significantly improved for patients treated with ranibizumab alone, or in combination with laser treatment compared with patients with laser treatment only. The strength of evidence for anti-VEGF is low. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.

Laser photocoagulation. Two before-after studies provided data. In one study, 105 patients with PDR and DME reported high scores on the DTSQ at 9 months following surgery. In the second study, 110 patients with DME and NPDR reported a statistically significant improvement in HRQL at 3 months following surgery. While HRQL improved following surgery, the strength of evidence is insufficient to draw conclusions about the effect of laser photocoagulation in improving HRQL.

Vitrectomy. One cohort study and one before-after study provided data. In the cohort study, 99 patients with PDR reported a statistically significant improvement on the VFQ–25 (Japanese version) at 3 months following surgery. For those with DME (n = 38), the score improved, but the change was not statistically significant. The score on the VFQ–25 for the normal control group was significantly higher than the preoperative and postoperative scores of patients with PDR and DME. In the before-after study, 41 patients with vitreous hemorrhage reported statistically significant improvements on the VFQ–25 (Japanese version) at 6 months following surgery. This contrasts with patients with DME (n = 28) and fibrovascular membrane (n = 18) who reported no significant change in HRQL. While HRQL improved for some subgroups of patients, the strength of evidence is insufficient to draw conclusions about the effect of vitrectomy in improving HRQL.

Vitrectomy and panretinal photocoagulation. One cohort study provided data for 327 patients with DR. Of these, 136 underwent vitrectomy, 60 received panretinal photocoagulation, and 131 had no treatment and served as a comparison group. For the vitrectomy group, there was a statistically significant improvement in the VFQ–25 (Japanese version) composite score at 1 year following surgery. Changes in the VFQ–25 scores for the comparison group and the photocoagulation group were not statistically significant. The strength of evidence is insufficient to draw conclusions about the relative effect of vitrectomy versus panretinal photocoagulation in improving HRQL.

Phacoemulsification for cataract surgery. Two cohort studies provided data. One study evaluated visual function using the VF–14 after first-eye phacoemulsification cataract surgery. Three months following surgery, 94 percent of patients reported improved visual acuity and 93 percent reported improvements in visual function. Patients with no or mild DR demonstrated significantly greater improvements in visual acuity and function compared with patients with more advanced disease. The second study followed 89 diabetic patients with bilateral cataracts. At 12 months following surgery, patients with PDR had the lowest VF–14 scores at baseline and improved marginally over the study period regardless of whether they had cataract surgery on one or both eyes. A similar pattern was seen for patients with moderate/severe NPDR. For patients with no or mild NPDR, maximum VF–14 scores at 12 months were significantly higher than for patients with more severe DR. While HRQL improved, the strength of evidence is insufficient to draw conclusions about the effect of this surgery in improving HRQL.

Factors associated with outcomes. No conclusions can be drawn about factors associated with HRQL outcomes. In one study, multivariate analysis found that age <65 years, more severe level of DR, and low preoperative QOL were associated with improved HRQL following laser photocoagulation. In another study that also investigated laser photocoagulation, univariate analysis showed an association between age and treatment satisfaction, with older patients (>65 years) being more satisfied. In a study of vitrectomy, multivariate analysis showed that improvement in contrast sensitivity was significantly correlated with changes in the VFQ–25 for patients with PDR and DME. There was no significant correlation between VFQ–25 and visual acuity.