# References

1 Congdon N, O'Colmain B, Klaver CC, et al. (2004). Causes and prevalence of visual impairment among adults in the United States. Arch Ophthalmol.
2 Zhang X, Saaddine JB, Chou CF, et al. (2010). Prevalence of diabetic retinopathy in the United States, 2005-2008. JAMA.
3 Saaddine JB, Honeycutt AA, Narayan KMV, et al. (2008). Projection of diabetic retinopathy and other major eye diseases among people with diabetes mellitus: United States, 2005-2050. Arch Ophthalmol.
4 (1993). The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. N Engl J Med.
5 Matthews DR, Stratton IM, Aldington SJ, et al. (2004). Risks of progression of retinopathy and vision loss related to tight blood pressure control in type 2 diabetes mellitus: UKPDS 69. Arch Ophthalmol.
6 Fong DS, Ferris FL, Davis MD, et al. (1999). Causes of severe visual loss in the early treatment diabetic retinopathy study: ETDRS report no. 24. Early Treatment Diabetic Retinopathy Study Research Group. Am J Ophthalmol.
7 Javitt JC, Aiello LP. (1996). Cost-effectiveness of detecting and treating diabetic retinopathy. Ann Intern Med.
8 American Academy of Opthalmology Retina Panel. (2008). Preferred practice pattern: diabetic retinopathy.
9 American Diabetes Association. (2011). Standards of Medical Care in Diabetes--2011. Diabetes Care.
10 American Optometric Association. (2005). Comprehensive adult eye and vision examination.
11 Vijan S, Hofer TP, Hayward RA. (2000). Cost-utility analysis of screening intervals for diabetic retinopathy in patients with type 2 diabetes mellitus. JAMA.
12 (1985). Photocoagulation for diabetic macular edema. Early Treatment Diabetic Retinopathy Study report number 1. Early Treatment Diabetic Retinopathy Study research group. Arch Ophthalmol.
13 (1987). Photocoagulation for diabetic macular edema: Early Treatment Diabetic Retinopathy Study Report no. 4. The Early Treatment Diabetic Retinopathy Study Research Group. Int Ophthalmol Clin.
14 Flynn HW, Chew EY, Simons BD, et al. (1992). Pars plana vitrectomy in the Early Treatment Diabetic Retinopathy Study. ETDRS report number 17. The Early Treatment Diabetic Retinopathy Study Research Group. Ophthalmology.
15 Nguyen QD, Shah SM, Khwaja AA, et al. (2010). Two-year outcomes of the ranibizumab for edema of the mAcula in diabetes (READ-2) study. Ophthalmology.
16 (1976). Preliminary report on effects of photocoagulation therapy. The Diabetic Retinopathy Study Research Group. Am J Ophthalmol.
17 Coyne KS, Margolis MK, Kennedy-Martin T, et al. (2004). The impact of diabetic retinopathy: perspectives from patient focus groups. Family Practice.
18 Woodcock A, Bradley C, Plowright R, et al. (2004). The influence of diabetic retinopathy on quality of life: interviews to guide the design of a condition-specific, individualised questionnaire: the RetDQoL. Patient Educ Couns.
19 Sharma S, Oliver-Fernandez A, Bakal J, et al. (2003). Utilities associated with diabetic retinopathy: results from a Canadian sample. Evidence-Based Eye Care.
20 Sharma S, Oliver-Fernandez A, Liu W, et al. (2005). The impact of diabetic retinopathy on health-related quality of life. Curr Opin Ophthalmol.
21 Baiardini I, Bousquet PJ, Brzoza Z, et al. (2010). Recommendations for assessing patient-reported outcomes and health-related quality of life in clinical trials on allergy: a GA(2)LEN taskforce position paper. Allergy.
22 Patrick DL, Burke LB, Powers JH, et al. (2007). Patient-reported outcomes to support medical product labeling claims: FDA perspective. Value Health.
23 Guyatt GH, Feeny DH, Patrick DL. (1993). Measuring health-related quality of life. Ann Intern Med.
24 Patrick DL, Bergner M. (1990). Measurement of health status in the 1990s. Annu Rev Public Health.
25 Revicki DA, Osoba D, Fairclough D, et al. (2000). Recommendations on health-related quality of life research to support labeling and promotional claims in the United States. Qual Life Res.
26 Higginson IJ, Carr AL, Robinson PG. (2003). Quality of Life.
27 McDowell I, Newell C. (2006). The theoretical and technical foundations of health measurement. Measuring health, a guide to rating scales and questionnaires.
28 de Boer MR, Moll AC, de Vet HC, et al. (2004). Psychometric properties of vision-related quality of life questionnaires: a systematic review. Ophthalmic Physiol Opt.
29 Mokkink LB, Terwee CB, Patrick DL, et al. (2010). The COSMIN study reached international consensus on taxonomy, terminology, and definitions of measurement properties for health-related patient-reported outcomes. J Clin Epidemiol.
30 (2002). Assessing health status and quality-of-life instruments: attributes and review criteria. Qual Life Res.
31 Hays RD, Anderson R, Revicki D. (1993). Psychometric considerations in evaluating health-related quality of life measures. Qual Life Res.
32 Johnson D, Hollands S, Hollands H, et al. (2010). Quality of life amongst American vs. Canadian patients with retinal diseases. Curr Opin Ophthalmol.
33 Lopes De Jesus CC, Atallah AN, Valente O, et al. (2008). Pentoxifylline for diabetic retinopathy. Cochrane Database of Systematic Reviews.
34 O'Doherty M, Dooley I, Hickey-Dwyer M. (2008). Interventions for diabetic macular oedema: a systematic review of the literature. Br J Ophthalmol.
35 Speight J, Reaney MD, Barnard KD. (2009). Not all roads lead to Rome - A review of quality of life measurement in adults with diabetes. Diabet Med.
36 Mokkink LB, Terwee CB, Knol DL, et al. (2010). The COSMIN checklist for evaluating the methodological quality of studies on measurement properties: a clarification of its content. BMC Med Res Methodol.
37 Albers G, Echteld MA, de Vet HC, et al. (2010). Evaluation of quality-of-life measures for use in palliative care: a systematic review. Palliat Med.
38 (2011). Higgins J, Green S, editors. Cochrane handbook for systematic reviews of interventions.
39 Wells GA, Shea B, O'Connel D, et al. (2011). The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomized studies in meta-analysis.
40 Owens DK, Lohr KN, Atkins D, et al. (2008). Grading the strength of a body of evidence when comparing medical interventions. Agency for Healthcare Research and Quality.
41 Okamoto F, Okamoto Y, Fukuda S, et al. (2010). Vision-related quality of life and visual function after vitrectomy for various vitreoretinal disorders. Invest Ophthalmol Vis Sci.
42 Sultan MB, Zhou D, Loftus J, et al. (2011). A phase 2/3, multicenter, randomized, double-masked, 2-year trial of pegaptanib sodium for the treatment of diabetic macular edema. Ophthalmology.
43 Okamoto F, Okamoto Y, Fukuda S, et al. (2008). Vision-related quality of life and visual function following vitrectomy for proliferative diabetic retinopathy. Am J Ophthalmol.
44 Loftus JV, Sultan MB, Pleil AM, et al. (2011). Changes in vision- and health-related quality of life in patients with diabetic macular edema treated with pegaptanib sodium or sham. Invest Ophthalmol Vis Sci.
45 Emi K, Oyagi T, Ikeda T, et al. (2008). Nippon Ganka Gakkai Zasshi.
46 Emi K, Ikeda T, Bando H, et al. (2009). Nippon Ganka Gakkai Zasshi.
47 Mitchell P, Bandello F, Schmidt-Erfurth U, et al. (2011). The RESTORE study: ranibizumab monotherapy or combined with laser versus laser monotherapy for diabetic macular edema. Ophthalmology.
48 Tranos PG, Topouzis F, Stangos NT, et al. (2004). Effect of laser photocoagulation treatment for diabetic macular oedema on patient's vision-related quality of life. Current Eye Research.
49 Matza LS, Rousculp MD, Malley K, et al. (2008). The longitudinal link between visual acuity and health-related quality of life in patients with diabetic retinopathy. HEALTH QUAL LIFE OUTCOMES.
50 Boisjoly H, Gresset J, Charest M, et al. (2002). The VF-14 index of visual function in recipients of a corneal graft: a 2-year follow-up study. Am J Ophthalmol.
51 Mozaffarieh M, Heinzl H, Sacu S, et al. (2009). Second eye cataract surgery in the diabetes patient?Quality of life gains and speed of visual and functional rehabilitation. Ophthalmic Research.
52 Hernaez-Ortega MC, Soto-Pedre E, Pinies JA. (2008). Lanreotide Autogel for persistent diabetic macular edema. DIABETES RES CLIN PRACT.
53 Mozaffarieh M, Heinzl H, Sacu S, et al. (2005). Clinical outcomes of phacoemulsification cataract surgery in diabetes patients: visual function (VF-14), visual acuity and patient satisfaction. Acta Ophthalmol Scand.
54 Mozaffarieh M, Benesch T, Sacu S, et al. (2005). Photocoagulation for diabetic retinopathy: determinants of patient satisfaction and the patient-provider relationship. Acta Ophthalmol Scand.
55 Scanlon PH, Martin ML, Bailey C, et al. (2006). Reported symptoms and quality-of-life impacts in patients having laser treatment for sight-threatening diabetic retinopathy. Diabet Med.
56 Ware JE, Sherbourne CD. (1992). The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care.
57 McHorney CA, Ware JE, Lu JF, et al. (1994). The MOS 36-item Short-Form Health Survey (SF-36): III. Tests of data quality, scaling assumptions, and reliability across diverse patient groups. Med Care.
58 Stucki G, Liang MH, Phillips C, et al. (1995). The Short Form-36 is preferable to the SIP as a generic health status measure in patients undergoing elective total hip arthroplasty. Arthritis Care Res.
59 Brazier JE, Harper R, Jones NM, et al. (1992). Validating the SF-36 health survey questionnaire: new outcome measure for primary care. BMJ.
60 Andresen EM, Patrick DL, Carter WB, et al. (1995). Comparing the performance of health status measures for healthy older adults. J Am Geriatr Soc.
61 Lyons RA, Perry HM, Littlepage BN. (1994). Evidence for the validity of the Short-form 36 Questionnaire (SF-36) in an elderly population. Age Ageing.
62 Hayes V, Morris J, Wolfe C, et al. (1995). The SF-36 health survey questionnaire: is it suitable for use with older adults?. Age Ageing.
63 Mangione CM, Lee PP, Gutierrez PR, et al. (2001). Development of the 25-item National Eye Institute Visual Function Questionnaire. Arch Ophthalmol.
64 Klein R, Moss SE, Klein BE, et al. (2001). The NEI-VFQ-25 in people with long-term type 1 diabetes mellitus: the Wisconsin Epidemiologic Study of Diabetic Retinopathy. Arch Ophthalmol.
65 Suzukamo Y, Oshika T, Yuzawa M, et al. (2005). Psychometric properties of the 25-item National Eye Institute Visual Function Questionnaire (NEI VFQ-25), Japanese version. HEALTH QUAL LIFE OUTCOMES.
66 Steinberg EP, Tielsch JM, Schein OD, et al. (1994). The VF-14. An index of functional impairment in patients with cataract. Arch Ophthalmol.
67 Bradley C. (1994). Diabetes treatment satisfaction questionnaire (DTSQ). Bradley C, editor. Handbook of psychology and diabetes: a guide to psychological measurement in diabetes research and management.
68 Bradley C, Speight J. (2002). Patient perceptions of diabetes and diabetes therapy: assessing quality of life. Diabetes Metab Res Rev.
69 Bradley C, Todd C, Gorton T, et al. (1999). The development of an individualized questionnaire measure of perceived impact of diabetes on quality of life: the ADDQoL. Qual Life Res.
70 Brose LS, Bradley C. (2010). Psychometric development of the individualized Retinopathy-Dependent Quality of Life questionnaire (RetDQoL). Value Health.
71 Brose LS, Bradley C. (2009). Psychometric development of the retinopathy treatment satisfaction questionnaire (RetTSQ). Psychology Health & Medicine.
72 Ware JE, Gandek B. (1998). Overview of the SF-36 Health Survey and the International Quality of Life Assessment (IQOLA) Project. J Clin Epidemiol.
73 Mangione CM, Lee PP, Pitts J, et al. (1998). Psychometric properties of the National Eye Institute Visual Function Questionnaire (NEI-VFQ). NEI-VFQ Field Test Investigators. Arch Ophthalmol.
74 Cassard SD, Patrick DL, Damiano AM, et al. (1995). Reproducibility and responsiveness of the VF-14. An index of functional impairment in patients with cataracts. Arch Ophthalmol.
75 Lewis KS, Bradley C, Knight G, et al. (1988). A measure of treatment satisfaction designed specifically for people with insulin-dependent diabetes. Diabet Med.
76 Horsman J, Furlong W, Feeny D, et al. (2003). The Health Utilities Index (HUI): concepts, measurement properties and applications. HEALTH QUAL LIFE OUTCOMES.
77 Kaplan SH, Greenfield S, Ware JE. (1989). Assessing the effects of physician-patient interactions on the outcomes of chronic disease. Med Care.
78 Sherbourne CD, Hays RD, Ordway L, et al. (1992). Antecedents of adherence to medical recommendations: results from the Medical Outcomes Study. J Behav Med.
79 Nguyen QD, Brown DM, Marcus DM, et al. (2012). Ranibizumab for Diabetic Macular Edema: Results from 2 Phase III Randomized Trials: RISE and RIDE. Ophthalmology.
80 Schulz KF, Altman DG, Moher D. (2010). CONSORT 2010 statement: updated guidelines for reporting parallel group randomised trials. PLoS Med.
81 Woodcock A, Plowright R, Kennedy-Martin T, et al. (2005). Development of the new retinopathy treatment satisfaction questionnaire (RetTSQ). International Congress Series.