# Methods

## Literature Search

In consultation with a research librarian we conducted a comprehensive search of the literature to identify relevant studies to answer the Key Questions. A single search strategy was developed to locate literature to address all four questions and was run in July 2010 in the following databases: MEDLINE®, EMBASE®, PsychINFO®, Cochrane Central Register of Controlled Trials®, CINAHL Plus full text, and Scopus. The search was updated in March 2011 in MEDLINE®, EMBASE®, Cochrane Central Register of Controlled Trials®. PubMed was also searched at this time to ensure that all current literature was captured. A final updated search of all databases was conducted in January 2012. No date or language restrictions were applied. In all databases both subject headings and key word terms for “diabetes,” “diabetic retinopathy,” “quality of life,” and “health-related quality of life” were included in the search. Appendix A contains a detailed description of the search strategy. We also conducted a search of clinicaltrials.gov for recently completed or ongoing studies of interest. The search was run in November 2010 then updated in April 2011 and used “diabetic retinopathy” as the main search term. The search was limited by study type (interventional studies) in adult participants.

To supplement the database searches we hand searched the reference lists of included studies and recently published review articles.20,32-35

## Study Selection

We used a two-step process for study selection. First, three reviewers (AM, ES, KR) independently screened the titles and abstracts (when available) located through the literature search to determine if an article met broad inclusion criteria. Studies were classed as “include,” “exclude,” or “unsure.” We retrieved the full-text of studies identified as “include,” or “unsure,” by at least one reviewer. Second, two reviewers (AM, KR) independently assessed each study using a standard inclusion-exclusion form (Appendix B). Disagreements were resolved through discussion between reviewers, or third party adjudication, as needed.

Our inclusion criteria are described below. Only articles published in full were considered for inclusion in this review (i.e., conference abstracts were not considered). We did not exclude studies based on their language of publication.

### Study Design

For Key Question 1a and b all study designs were included.

For Key Questions 2 and 3, only prospective study designs with a comparator (i.e., randomized controlled trials (RCT), nonrandomized controlled trials (NRCT), quasi-experimental studies—including, but not limited to, controlled before-after studies—and prospective cohort studies) were included. Retrospective studies were excluded.

### Population

For all questions, we included studies that recruited adults (≥18 years) who had been diagnosed with diabetic retinopathy (DR) including diabetic macular edema (DME), nonproliferative diabetic retinopathy (NPDR), proliferative diabetic retinopathy (PDR), and other related conditions.

### Intervention and comparator

For all questions, we considered any intervention and comparator including comparisons of different types of interventions, different doses, or different formulations.

### Outcome

For Key Questions 1a and 1b, any measurement instrument that included at least one domain of HRQL (i.e., physical, mental, emotional, social functioning) was considered.

For Key Questions 2 and 3, only outcomes based on measurement instruments with published data on the instrument's psychometric properties were included.

## Data Extraction

Data were abstracted directly into evidence tables in a Microsoft Word^™^ document (Microsoft Corp., Redmond, WA). One reviewer abstracted data which was then checked for accuracy and completeness by a second reviewer. Disagreements were resolved through discussion or third party adjudication, as needed. The following data were extracted for Key Questions 1a and 1b: title of HRQL instrument, author(s), year of publication, instrument characteristics (target population, QOL domains measured, number of items, number of response options, scoring algorithm, time needed to complete, and mode of administration), and quality assessment for measurement properties.

The following data were extracted for Key Questions 2 and 3: author(s), year of publication, date of study, study setting, study characteristics (study design, inclusion/exclusion criteria, intervention, and comparator), study population (age, sex, type of diabetes, visual acuity, type of DR, and other retinal diseases), HRQL instrument(s) used, and results for the outcomes of interest.

## Assessment of Methodological Quality

### Quality Assessment of HRQL Tools

For Key Question 1b, we used the COSMIN29,36 checklist to assess the quality of the HRQL instruments. The checklist includes seven items: content and construct validity, internal consistency, reliability, absolute measurement error, responsiveness, and interpretability.37 Each item is rated with the following options: “not done,” or “low,” “indeterminate,” or “high” quality. Validity, reliability, and responsiveness depend on the setting and the population in which they are assessed. Therefore, descriptions of the study population characteristics, measurements, settings, and data analysis of every individual study were rated. If a description was lacking, the item was rated as indeterminate. One reviewer assessed the HRQL instruments in consultation with an expert in the HRQL field.

### Quality Assessment for Included Studies

For Key Question 2, we assessed trials using the Cochrane Risk of Bias (ROB) tool for RCTs.38 The ROB includes six domains which assess sequence generation, allocation concealment, blinding (participants and personnel, and outcome assessors), incomplete outcome data, selective outcome reporting, and other sources of bias. Each domain is assessed as “low,” “unclear,” or “high” based on the predefined criteria layed out the Cochrane Handbook, and the study is given an overall rating based on the assessment of each domain.

We used a modified version of the Newcastle-Ottawa Scale (NOS) for cohort studies.39 The NOS includes seven items assessing sample selection, comparability of cohorts, and the assessment of outcomes. One star was allotted for each item that was adequately addressed in the study, with the exception of the comparability of cohorts, for which a maximum of two stars could be given. The overall score was calculated by tallying the stars, with a total possible score of eight stars.

The methodological quality of before-after studies was assessed using a modified version of the NOS that assessed sample selection and the assessment of outcomes. One star was allotted for each item that was adequately addressed in the study. The overall score was calculated by tallying the stars, with a total possible score of five stars.

Two reviewers (AM, CS, DD) independently assessed the methodological quality of the included studies. Decision rules were developed a priori through discussions with content and methodology experts. Discrepancies in quality assessment were resolved through consensus.

## Data Analysis

For Key Question 1, we developed summary tables of the HRQL instruments, their characteristics, and their psychometric properties. For Key Question 2, we developed summary evidence tables of the study and population characteristics, and outcomes. Key Question 3 is presented in a descriptive analysis.

Mean differences (MD) and 95 percent confidence intervals (95% CI) were calculated for continuous variables. Missing means were approximated by medians. Missing standard deviations were computed from standard errors, confidence intervals, or p-values. If none of these were available, they were estimated from ranges or interquartile ranges, or imputed from other similar studies with the same outcome. We did not conduct any meta-analyses due to the heterogeneity of interventions and patient characteristics.

## Grading the Evidence for Key Question 2

We used the EPC GRADE approach40 to assess the strength of evidence for HRQL. The following four major domains were examined: risk of bias (incorporating both study design and study conduct), consistency, directness, and precision. An overall evidence grade based on the ratings for the individual domains was assigned. The overall strength of evidence was graded as “high” (indicating high confidence that the evidence reflects the true effect and further research is very unlikely to change our confidence in the estimate of effect); “moderate” (indicating moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of effect and may change the estimate); “low” (indicating low confidence that the evidence reflects the true effect and further research is likely to change our confidence in the estimate of effect and is likely to change the estimate); and “insufficient” (indicating that evidence is either unavailable or does not permit estimation of an effect). The strength of evidence was graded by one reviewer.