# Introduction

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from the Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the following Evidence-based Practice Center: University of Alberta Evidence-based Practice Center (Contract No. HHSA 290 2007 10021 I).

## Diabetic Retinopathy

Diabetic retinopathy (DR) is a leading cause of vision loss in the United States and occurs as a result of pathologic changes of the retinal vasculature.1 In 2005–2008, the estimated crude prevalence among Americans over the age of 40 with diabetes was 28.5 percent. Although the prevalence of vision-threatening DR is approximately 4.4 percent,2 the number of affected Americans 40 years or older is expected to triple from 1.2 million in 2005 to 3.4 million in 2050.^3^ The prevalence and severity of DR increases with the duration of diabetes; however, it is inversely correlated to glycemic and blood pressure control.4,5 Moderate vision loss is most commonly related to retinal leakage within the macula, while severe vision loss usually occurs as a result of neovascularization (proliferative diabetic retinopathy; PDR) with subsequent hemorrhage or fibrosis.6

Early identification and treatment of DR is an important goal for patients and health systems because treatment is both cost-effective and reduces vision loss.7 Therefore, early detection is critical; the American Academy of Ophthalmologists, the American Optometric Association, and the American Diabetes Association recommend an annual dilated eye examination for all people with diabetes, and more frequent eye examinations for people with known DR.8-10 Other researchers argue that the frequency of examinations should be stratified to an individual's risk of progression and vision loss.11

The mainstay of DR treatment is aimed at reducing the risk of onset and limiting the progression of the disease. Therefore, retinal assessments should be performed on a regular basis to determine the presence and degree of DR, glycemic control should be optimized, and known risk factors such as blood pressure, dyslipidemia, elevated cholesterol, renal disease and abdominal obesity should be controlled. Direct ocular therapy should be prescribed when indicated, while vision rehabilitation and low vision aids should to be used to maximize vision if there is a loss.4,5

Until recently, the primary treatment for DR has been focal or grid laser of the retina.12,13 Serial intravitreal injections of triamcinolone have been introduced as a treatment option as they have been shown to be effective in reducing diabetic macular edema (DME); however, their use has become less common due to significant adverse effects including elevated intraocular pressure and cataract formation.14,15 Ranibizumab and becvacizumab are being used with increasing frequency for the treatment of DME; however they have not yet been approved for use in this condition by the Food and Drug Administration. The recommended treatment of PDR remains panretinal photocoagulation16 with vitrectomy surgery performed when necessary.14 It is important to note that treatment of DR is not always aimed at restoration of pre-disease visual acuity, but rather at limiting further deterioration. Patients may report a decrease in visual acuity immediately after therapy, which may manifest in low initial perceptions of treatment satisfaction. However, results from the Early Treatment Diabetic Retinopathy Study demonstrate that early treatment with either panretinal photocoagulation or vitrectomy prevents long-term disability due to blindness.12-14

Vision loss is particularly debilitating for patients with diabetes because treatment success to limit progression of their diabetes depends upon their ability to read a glucometer and inject subcutaneous insulin. Diabetic patients with retinopathy have reported that vision loss impacts multiple areas of well-being including: independence, mobility, leisure, and self-care.7,17,18 Additionally, DR has been found to impair functioning and overall health-related quality of life (HRQL).19,20

## Health-Related Quality of Life

### Patient-Reported Outcomes

In recent years clinicians and researchers have given greater recognition to the subjective experiences of patients diagnosed with chronic illnesses such as diabetes mellitus. This increase in attention targets a more holistic understanding of the patient and how treatments purported to curtail long-term complications of chronic illnesses, such as DR, affect daily physical and psychosocial functioning.21 Patient reported outcomes (PROs) are a group of outcomes used to measure a wide variety of aspects of care including HRQL, patient illness perceptions, and treatment satisfaction or adherence.21 PROs can be distinguished from other outcomes such as laboratory results and clinician or caregiver ratings because the report is from the patient's perspective, usually without interpretation by another individual.22 Furthermore, PROs are dependent on disease-related dimensions, such as the degree of visual impairment caused by DR.21 Researchers are more frequently including PROs as a part of clinical trials as they help demonstrate benefit, survival, and patient feelings regarding treatments.22 However, PROs tend to be evaluated as a secondary outcome, and are rarely the primary outcome of a trial.21

### Health Status/Functional Status

Included under the umbrella of PROs are the terms: health status, functional status, and quality of life (QOL) or HRQL. These terms are frequently used interchangeably to mean “health”; however, researchers caution that they have distinct meanings and uses.23,24 Health status is often used to refer to the identification and assessment of changes in patients' activities and perceptions compared with normal life.24 This construct is multidimensional and represents patients' subjective evaluations of their physical and mental health.25 Functional status focuses on the physical capacity to complete everyday activities at home or work, rather than patients' perceptions of how their health affects their functioning.25 Health status is effective in monitoring the status of a community or local population and can be used in setting health priorities, identifying high risk groups, estimating service needs, and analyzing usage patterns.24 HRQL and QOL delve further into patient perceptions of health and well-being.

### Health-Related Quality of Life/Quality of Life

QOL covers a range of experiences related to patients' well-being based on their subjective experiences.25 Many variables, both objective and subjective, interact to define QOL,26 but it is dependent upon individual patient experiences, states, and perceptions of their illness.25 QOL can vary as a result of life events or changes in functional health status, with each area of QOL impacting the others.26 In the case of patients with diabetes, comorbidities and complications such as renal disease or dialysis, neuropathy, gastroparesis, amputation, impotence and erectile dysfunction all play a part in influencing QOL. Furthermore, the level of visual acuity, glycemic control, and duration of disease can impact directly on vision-related QOL.

HRQL allows clinicians and researchers to measure the impact of chronic diseases such as diabetes mellitus on the lives of patients.23 As with QOL, HRQL is a multifaceted measurement. It takes into account the impact of disease and its treatments on physical, psychological, social, and somatic domains of functioning and well-being.25 Therefore, in patients diagnosed with DR, treatments that improve visual acuity also have the potential to positively impact HRQL by allowing them to continue participating, or to increase their ability to participate, in the daily activities of their lives. Various domains can be included in the evaluation of HRQL including physical, psychological, and social assessments. Some definitions may include broader terms such as global perceptions of functioning and general well-being.25 Several different views exist on how to measure QOL and HRQL, in large part due their subjective nature, but also due to the lack of distinction between indicator and causal variables, as well as mediating variables.26

### Measuring Health-Related Quality of Life/Quality of Life

As patient-centered health care grows in importance, clinicians and researchers need a way to make health care decisions that meet the needs of patients. It is critical to ensure that treatment decisions meet patient and societal values, and to recognize that perceptions of HRQL may vary between the patient and clinicians.25 Furthermore, investigations into public perceptions of HRQL and QOL suggest that areas judged important by the general public have not been included in some commonly used measurement tools.26 Collecting HRQL and QOL outcomes allows clinicians and researchers to take into account a wider array of information that cannot be obtained through laboratory or physical measures, and permit a subjective description of functioning alongside objective findings.27 Through the collection of patient perceptions of interventions used to treat DR, health care providers can better understand what aspects of health patients value most highly and therefore what types of treatment may provide the greatest benefit.

Just as the definitions of HRQL and QOL vary, so too do the tools used for evaluating these outcomes. Evaluation tools may be as simple as a single question asking the patient to state their QOL; however, they are more likely to take the form of a questionnaire with multiple items, which investigate different domains related to HRQL.23 The common thread that exists among measurement tools is that they attempt to summarize the judgments patients make about their health and illness experiences.26 HRQL tools can be placed into two categories: generic instruments- and specific instruments.

Generic HRQL tools investigate all important aspects of HRQL and allow broad comparisons, but do not necessarily investigate a specific aspect of disease. Typically generic tools include questions relating to the four main domains of HRQL: physical, functional, social, and psychological health.28 These tools may be less responsive to change as they provide an overall summary score of HRQL, rather than a score on a precise area of health.23 Of the tools investigated in this review, one falls into the category of generic tools. The Short Form–36 (SF–36) questionnaire investigates eight health domains in patients with a variety of conditions and was developed for use in the general patient population.

Specific HRQL instruments are designed to target a disease, population, or an outcome. Where generic tools allow broad comparisons, specific tools may be more responsive to HRQL changes in the specific patient population under investigation.23 Two tools included in this review were developed specifically to evaluate patients with eye disease: the Visual Function-14 (VF-14), and the National Eye Institute Visual Function Questionnaire (VFQ) (both 25 and 51 item versions). These tools were designed for patients diagnosed with cataracts and low vision, respectively, but do not investigate the involvement of the underlying condition of diabetes mellitus on patient QOL. One tool included in this review, the Diabetic Treatment Satisfaction Questionnaire (DTSQ), evaluates treatment satisfaction in patients with diabetes mellitus. This measure is disease-specific but it does not take into account whether or not a patient is also diagnosed with DR. Two tools included in this review were developed to evaluate HRQL in patients with DR: the Retinopathy Treatment Satisfaction Questionnaire (RetTSQ), and the Retinopathy Dependent Quality of Life (RetDQoL) questionnaire. Since diabetic patients without retinopathy may have different concerns compared to those with retinopathy, these tools have the potential to provide a greater understanding of HRQL than a tool such as the DTSQ. Both of these tools have undergone a series of psychometric evaluations; however, to date neither has been used in published trials assessing the impact of an intervention for DR.

### Psychometric Properties for HRQL Tools

Regardless of whether a tool is generic or specific, it is helpful to accumulate evidence of its psychometric properties to ensure they provide the most reliable and valid assessment of health status in the patient population. Accompanying the growing interest in HRQL has been the increase in the number of tools available to measure such outcomes, which in turn can make it difficult for researchers and clinicians to determine what tools are the most trustworthy and appropriate for use in clinical and research settings. In recent years, researchers have undertaken the challenge of identifying what psychometric properties are of greatest importance when evaluating the quality of a HRQL tool, and what criteria should be used in judging the psychometric properties. In 2010 the COnsensus-based Standards for the selection of health Measurement INstruments (COSMIN) was released as a checklist for the purpose of evaluating the methodological quality of studies investigating the measurement properties of HRQL tools.29 The COSMIN researchers used a Delphi approach to reach consensus on what psychometric properties are considered the most important for high-quality HRQL measurement instruments. They also reached consensus on definitions for these psychometric properties.

Reliability. Reliability is the degree to which the tool is free from measurement error.29 Depending on the source of measurement error and how the measurement is obtained, reliability can take different forms. Internal consistency is a reflection of the reproducibility of measurement by different items within a multi-item scale. Test-retest reliability is the degree to which the score of a patient who has not changed clinically remains the same under repeated measurements;29 other groups refer to this as reproducibility.23,28,30 In order to ascertain test-retest reliability, measurements should be taken over an interval that is short enough to ensure that patients remain stable, but long enough to prevent recall bias. An interval of one to four weeks is considered sufficient.23 Internal consistency reliability is commonly assessed using Cronbach's coefficient α. Test-retest reliability is typically presented as a correlation coefficient between the two sets of measurements, either Pearson's R or intra-class correlation. The minimum standard inter-item correlation for multi-item scales, for either reliability coefficient, is 0.70 for group comparisons, and 0.90 to 0.95 for individual comparisons.30

Validity. Validity is defined as the degree to which an instrument measures the construct(s) it is intended to measure.29 The COSMIN panel identified three categories of validity: content validity, construct validity, and criterion validity. Content validity is concerned with the content of the measurement tool and whether it is an adequate reflection of the construct to be measured. Face validity is considered a part of this domain.29 Typically, there are no formal tests of content validity, but rather a subjective assessment, based in part on the item generation process during instrument development. Construct validity considers whether the scores produced by the instrument are consistent with the hypothesis of how the tool should behave, assuming the tool is valid.29 Achieving construct validity is often an iterative process.31 Construct validity is further broken down into structural validity, hypothesis testing, and cross-cultural validity. The final type of validity, criterion validity, focuses on the degree to which the scores of an instrument reflect a “gold standard.” Validity can be stronger when an instrument's results are tested against other known instruments;30 however, the existence of gold standards in HRQL measurement tools is limited, therefore researchers may have to find alternate methods of demonstrating criterion validity.23

Responsiveness. The responsiveness of a tool demonstrates the ability of the instrument to detect changes in a patient over time when changes in the construct being measured actually occur.29 Responsiveness, or a tool's sensitivity to change, is considered a specific type of construct validation when assessing change over time.30 Hypotheses regarding the relationship of the change in the instrument and how they correspond to changes in reference measures should be proposed and tested.28 Changes in HRQL measures can be compared with changes in a patient's health status, health events, interventions, or direct reports of change in QOL by patients or providers to help pinpoint the cause of variations in HRQL status.

Interpretability. The final domain considered by the COSMIN panel is interpretability. Interpretability is not seen as a psychometric property; rather it is important to assess the usability of the measurement tool. This domain is defined as the degree to which a clinician or researcher can equate a qualitative meaning to an instrument's quantitative score.29 In other words, interpretability is concerned with whether or not an instrument can easily be understood and be made meaningful to clinicians and their patients.30 Furthermore, interpretability is concerned with whether or not the score indicates that a patient is functioning normally, is experiencing moderate to severe impairment, or whether changes associated with treatments are small, medium or large.23

## Key Questions

The Centers for Medicare and Medicaid Services (CMS) requested a technology assessment on the effectiveness of interventions for DR to improve HRQL. Four questions were posed:

1a What HRQL measures have been used in studies of treatments for DR?
1b What are the psychometric properties of the HRQL measures used in the studies?
2 Including only studies that have used reliable and valid measures, what is the evidence that HRQL is improved for any intervention for DR? What is the comparative effectiveness of interventions to improve HRQL in patients with DR?
3 What evidence is presented in the studies about the relationship between the measured improvement in HRQL and any relevant variables, including but not limited to baseline visual acuity, age (≥ 65 years), race, sex, severity and type of DR (i.e. DME, nonproliferative diabetic retinopathy (NPDR), PDR)?

## Analytic Framework

Figure 1 depicts the four key questions and the linkages between the population of interest, the interventions, and outcome measures. It demonstrates the chain of logic that the evidence obtained must support the link between the interventions, modifying variables, and patient outcomes. This technology assessment focuses primarily on the effect of interventions for DR on HRQL (Q2). HRQL instruments may differ in their psychometric properties, and these differences could be a source of variation in outcomes among studies that use different instruments (Q1a and Q1b). HRQL outcomes may be modified by demographic and clinical factors due to the variation in baseline prevalence of these factors in different populations (Q3). The specific HRQL instruments that have been used in studies and their psychometric properties will be reported separately from the patient outcomes.

Figure 1 Analytic Framework