# Executive Summary

## Introduction

### Diabetic Retinopathy

Diabetic retinopathy (DR) is a leading cause of vision loss in the United States and occurs as a result of pathologic changes of the retinal vasculature.1 In 2005–2008, the estimated crude prevalence among Americans over the age of 40 with diabetes was 28.5 percent. Although the prevalence of vision-threatening DR is approximately 4.4 percent,2 the number of affected Americans 40 years or older is expected to triple from 1.2 million in 2005 to 3.4 million in 2050.^3^ The prevalence and severity of DR increases with the duration of diabetes; however, it is inversely correlated to glycemic and blood pressure control.4,5 Moderate vision loss is most commonly related to retinal leakage within the macula, while severe vision loss usually occurs as a result of neovascularization (proliferative diabetic retinopathy; PDR) with subsequent hemorrhage or fibrosis.6

Early identification and treatment of DR is important since treatment is both cost-effective and reduces vision loss.7 The American Academy of Ophthalmologists, the American Optometric Association, and the American Diabetes Association recommend an annual dilated eye examination for all people with diabetes, and more frequent eye examinations for people with known DR.8-10 Other researchers argue that the frequency of examinations should be stratified to an individual's risk of progression and vision loss.11

The mainstay of DR treatment is aimed at reducing the risk of onset and limiting the progression of the disease. Therefore, retinal assessments should be performed on a regular basis to determine the presence and degree of DR, glycemic control should be optimized, and known risk factors such as blood pressure, dyslipidemia, elevated cholesterol, renal disease and abdominal obesity should be controlled. Direct ocular therapy should be prescribed when indicated, while vision rehabilitation and low vision aids should to be used to maximize vision if there is a loss.4,5

Until recently, the primary treatment for DR has been focal or grid laser of the retina.12,13 Serial intravitreal injections of triamcinolone have been introduced as a treatment option as they have been shown to be effective at reducing diabetic macular edema (DME); however, their use is becoming less common due to significant adverse effects including elevated intraocular pressure and cataract formation.14,15 Ranibizumab and becvacizumab are being used with increasing frequency for the treatment of DME; however they have not yet been approved for use in this condition by the Food and Drug Administration. The recommended treatment of PDR remains panretinal photocoagulation16 with vitrectomy surgery performed when necessary.14 It is important to note that treatment of DR is not always aimed at restoration of pre-disease visual acuity, but rather at limiting further deterioration. Patients may report a decrease in visual acuity immediately after therapy, which may manifest in low initial perceptions of treatment satisfaction. However, results from the Early Treatment Diabetic Retinopathy Study demonstrate that early treatment with either panretinal photocoagulation or vitrectomy prevents long-term disability due to blindness.12-14

Diabetic patients with retinopathy have reported that vision loss impacts multiple areas of well-being including: independence, mobility, leisure, and self-care.7,17,18 Additionally, DR has been found to impair functioning and overall health-related quality of life (HRQL).19,20

### Health Related Quality of Life

Patient Reported Outcomes. Patient reported outcomes (PROs) measure a variety of aspects of care including HRQL, patient illness perceptions, and treatment satisfaction or adherence.21 PROs are distinguished from other outcomes because the report is from the patient's perspective, usually without interpretation by another individual.22 PROs include: health status, functional status, and quality of life (QOL) or HRQL.23,24 Health status refers to the identification and assessment of the changes in patients' activities and perceptions compared with normal life.24 Functional status focuses on the physical capacity to complete everyday activities at home or work. QOL covers a range of experiences related to patients' well-being based on their subjective experiences.25 Many variables, both objective and subjective, interact to define QOL,26 but it is dependent upon individual patient experiences, states, and perceptions of their illness.25 HRQL allows clinicians and researchers to measure the impact of chronic diseases such as diabetes mellitus on the lives of patients.23 It takes into account the impact of disease and its treatments on physical, psychological, social, and somatic domains of functioning and well- being.25

Measuring Health-Related Quality of Life/Quality of Life. Collecting HRQL and QOL outcomes allows clinicians and researchers to take into account a wider array of information that cannot be obtained through laboratory or physical measures, and provides a subjective description of functioning alongside objective findings.27 Through the collection of patient perceptions of interventions, health care providers can better understand what aspects of health patients value most highly and therefore what types of treatment may provide the greatest benefit.

Just as the definitions of HRQL and QOL vary, so too do the tools used for evaluating these outcomes. Evaluation tools may be as simple as a single question asking patients to state their QOL; however, they are more likely to take the form of a questionnaire with multiple items that investigate different domains related to HRQL.23 HRQL tools can be divided into two categories: generic instruments and specific instruments.

Generic HRQL tools investigate all important aspects of HRQL and allow broad comparisons, but do not necessarily investigate a specific aspect of disease.28 These tools may be less responsive to change as they provide an overall summary score of HRQL.23 Specific HRQL instruments target a particular disease, population, or an outcome. Where generic tools allow broad comparisons, specific tools may be more responsive to HRQL changes in the specific patient population under investigation.23

Psychometric Properties for HRQL Tools. The large number of HRQL tools that are available can make it difficult for researchers and clinicians to determine what tools are the most trustworthy and appropriate for use in clinical and research settings. In recent years, a group of international researchers has undertaken the challenge of identifying what psychometric properties are of greatest importance when evaluating the quality of a HRQL tool, and what criteria should be used in judging the psychometric properties. In 2010, the COnsensus-based Standards for the selection of health Measurement INstruments (COSMIN) checklist was released for the purpose of evaluating the methodological quality of studies investigating the psychometric properties of HRQL tools.29 The COSMIN researchers also reached consensus on definitions for these psychometric properties (Table ES1).

Table ES1 Definitions of psychometric properties

Domain | Psychometric Property | Definition
Reliability | | Reliability is the degree to which the tool is free from measurement error.
| Internal Consistency | Internal consistency reliability is a reflection of the reproducibility of measurement by different items within a multi-item scale.
| Test-retest Reliability | Test-retest reliability is the degree to which the score of a patient who has not changed remains the same under repeated measurements.
Validity | | Validity is defined as the degree to which an instrument measures the construct(s) it is intended to measure.
| Content Validity | Content validity is concerned with the content of the measurement tool and whether it is an adequate reflection of the construct to be measured.
| Construct Validity | Construct validity considers whether the scores produced by the instrument are consistent with the hypothesis of how the tool should behave, assuming the tool is valid.
| Criterion Validity | Criterion validity focuses on the degree to which the scores of an instrument reflect a ‘gold standard’.
Responsiveness | | The responsiveness of a tool demonstrates the ability of the instrument to detect changes in a patient over time when changes in the construct being measured actually occur.
Interpretability | | Interpretability is considered important for the usability of the measurement tool rather than as a psychometric property. It is the degree to which a clinician or researcher can equate a qualitative meaning to an instrument's quantitative score.

### Key Questions

1a What HRQL measures have been used in studies of treatments for DR?
1b What are the psychometric properties of the HRQL measures used in the studies?
2 Including only studies that have used reliable and valid measures, what is the evidence that HRQL is improved for any intervention for DR? What is the comparative effectiveness of interventions to improve HRQL in patients with DR?
3 What evidence is presented in the studies about the relationship between the measured improvement in HRQL and any relevant variables, including but not limited to baseline visual acuity, age (≥65 years), race, sex, severity, and type of DR (i.e., DME, nonproliferative diabetic retinopathy (NPDR), PDR)?

## Methods

### Literature Search

We conducted systematic and comprehensive searches in the following databases: MEDLINE®, EMBASE®, PsychINFO®, Cochrane Central Register of Controlled Trials®, CINAHL Plus full text, and Scopus to identify relevant studies to address the Key Questions. The searches were run in July 2010. An update search including PubMed was run in March 2011. A full search update was run in January 2012. No date or language restrictions were applied. We also conducted a search of ClinicalTrials.gov for recently completed or ongoing studies. To supplement the database searches, we hand searched the reference lists of review articles and included studies. We did not search for conference papers.

### Study Selection

Two reviewers independently screened titles and abstracts using broad inclusion criteria. The full text of articles identified as “include” or “unclear” were retrieved for formal review. Each article was independently assessed by two reviewers using detailed a priori inclusion criteria and a standardized form. Disagreements were resolved by consensus or by third party adjudication, as needed.

For all questions the population of interest was adults (≥18 years) with DR including DME, NPDR, PDR, and other related conditions. For Key Question 1, we included studies that reported the use of any measurement tool that included at least one domain of HRQL, and we considered all study designs. For Key Questions 2 and 3, we included prospective comparative studies that investigated any intervention. We included studies that used a HRQL measurement tool with published data on the instrument's psychometric properties. There were no language restrictions. We excluded studies that were only available as abstracts.

### Quality Assessment and Grading the Body of Evidence

Quality Assessment of HRQL Tools. We used the COSMIN29,36 checklist to evaluate the psychometric properties of HRQL instruments. The following domains were assessed: content and construct validity, internal consistency, reliability, absolute measurement error, responsiveness, and interpretability.37 Each domain was rated as “no data available,” “low quality,” “indeterminate,” or “high quality.” One reviewer assessed the HRQL tools in consultation with an expert in the HRQL field.

Quality Assessment of Included Studies. We assessed trials using the Cochrane Risk of Bias (ROB) tool for randomized controlled trials (RCTs).38 The ROB includes six domains which assess sequence generation, allocation concealment, blinding (participants and personnel, and outcome assessors), incomplete outcome data, selective outcome reporting, and other sources of bias.

We assessed cohort studies using a modified version of the Newcastle-Ottawa Scale (NOS) for cohort studies.39 The NOS includes seven items assessing sample selection, comparability of cohorts, and the assessment of outcomes. The methodological quality of before-after studies was assessed using the modified NOS that assessed sample selection and the assessment of outcomes. Two reviewers independently assessed the methodological quality; discrepancies were resolved through consensus or third party adjudication, as needed.

Grading the Evidence for Question 2. The overall strength of evidence for HRQL was assessed using the EPC GRADE approach.40 The following four domains were examined: risk of bias (including study design and study conduct), consistency, directness, and precision. The overall strength of evidence was graded as “high,” “moderate,” “low,” or “insufficient.” One reviewer rated the strength of evidence.

### Data Abstraction and Analysis

One reviewer extracted data directly into evidence tables, and a second reviewer checked the data for accuracy and completeness. Disagreements were resolved through discussion or third party adjudication, as needed.

We calculated mean differences and 95 percent confidence intervals (95% CI) for continuous variables. We did not conduct any meta-analysis due to the heterogeneity of interventions and patient characteristics.

## Results

### Literature Review

The electronic literature search identified 6,961 unique citations. Sixteen studies addressed Key Question 1a. Of these, 11 used validated HRQL measures (Key Question 1b). Nine primary studies provided data to address Key Questions 2 and 3.

### Key Question 1a What HRQL measures have been used in studies of treatments for diabetic retinopathy?

We identified four HRQL measures that have been used in studies assessing the treatment of DR. The most commonly used measure was the National Eye Institute Visual Functioning Questionnaire (VFQ). Five studies41,42,45-47 used the 25-item version (VFQ–25); one48 used the 51 item version (VFQ–51). In addition, seven recently completed trials that have not yet published their results reported using the VFQ–25. One study49 used both the VFQ–25 and the Medical Outcomes Study (MOS) 36–Item Short Form Health Survey (SF–36). Two studies46,47 used the Visual Function Index (VF–14). One study used both the VF–14 and the MOS 12–Item Short Form Health Survey (SF–12),52 and another study53 used the VF–14 plus a questionnaire to assess satisfaction with surgical outcomes. One study54 used the Diabetes Treatment Satisfaction Questionnaire (DTSQ) plus a questionnaire to assess the degree to which treatment outcomes corresponded to patient expectations. One study55 used qualitative interviews to assess QOL but did not use a specific measure.

We also identified two HRQL measures that have been developed specifically for patients with DR: the Retinopathy Treatment Satisfaction Questionnaire (RetTSQ), and the Retinopathy Dependent Quality of Life (RetDQoL) measure. The HRQL assessment tools are described in Table ES2.

ES2 Description of health-related quality of life assessment tools

Instrument | Administration | Domains Measured | Scoring
Generic HRQL assessment tools
Short Form–36 (SF–36) | Target population: general pt population, aged >14 yr Mode of administration: self-complete questionnaire Time needed to complete: 5–10 minutes | Physical functioning; Role limitations because of physical health problems; Bodily pain; Social functioning; General mental health; Role limitations because of emotional problems; Vitality; General health perceptions; Health transition Items: 8 items (excluding health transition) | Possible range: 0 (least favorable) to 100 (most favorable)
Low-vision HRQL assessment tools
National Eye Institute Visual Function Questionnaire–25 (VFQ–25) | Target population: pt with low vision Mode of administration: pt interview; self- administered Time needed to complete: 5 minutes | Overall health Overall vision; Difficulty with: i) near vision; ii) distance vision; Limitations in social functioning; Role limitations; Dependency on others; Mental health symptoms; Driving difficulties; Pain and discomfort around the eyes; Peripheral vision; Color vision Items: 25 or 26 items (versions vary between 2 and 3 questions in the driving domain) | Possible range: 0 (most severe impairment) to 100 (no impairment)
Visual Function–14 (VF–14) | Target population: pt treated with cataract surgery Mode of administration: NR Time needed to complete: NR | Vision dependent functional activities: e.g. reading; recognizing people; seeing steps, stairs or curbs; doing fine handwork; writing checks or filling out forms; playing games, taking part in sports, cooking, watching television; and driving Items: 18 questions cover 14 items | Possible range: 0 (most severe impairment) to100 (no impairment)
Diabetes-related HRQL assessment tools
Diabetes Treatment Satisfaction Questionnaire Status Version (DTSQs) | Target population: pt with DM Mode of administration: self-completed questionnaire Time needed to complete: NR | Treatment Satisfaction; Perceived frequency of hyperglycemia; Perceived frequency of hypoglycemia Items: 8 items | Possible range: Treatment Satisfaction: 0 (most dissatisfied) to 36 (most satisfied); Perceived frequency of hyperglycemia/hypoglycemia: 0 (least frequent) to 6 (most frequent)
Diabetic retinopathy-related HRQL assessment tools
Retinopathy Dependent Quality of Life (RetDQoL) | Target population: pt with DR Mode of administration: paper based questionnaire Time needed to complete: NR | Retinopathy-dependent quality of life: e.g. household tasks; personal affairs; shopping; feelings about the future/past; working life; close personal relationship; family life; social life Items: 24 items, also assesses the importance of each item to the pt | Possible range: -9 (max negative impact of DR on QOL) to 3 (max positive impact of DR on QOL)
Retinopathy Treatment Satisfaction Questionnaire (RetTSQ) | Target population pt with DR Mode of administration: paper based questionnaire Time needed to complete: NR | Satisfaction of treatment for DR: e.g. tx satisfaction, perceived effectiveness of tx; tx side effects; discomfort or pain; unpleasantness of tx; difficulty of tx; feelings of apprehension r/t tx; feelings of satisfaction regarding influence over tx; safety of tx; time-consumed by tx; Items: 13 items asking pt to rate different aspects of treatment | Possible range: 0 (worst) to 78 (best)

DM = diabetes mellitus; DR = diabetic retinopathy; NR = not reported; pt = patient; QOL = quality of life tx = treatment; yr = year

### Key Question 1b What are the psychometric properties of the HRQL measures used in the studies?

The six HRQL tools can be separated into two broad groups: generic and specific. The latter category can be further divided into tools developed for use in populations with low vision, diabetes mellitus, and DR. Table ES3 presents a summary of the ratings of the psychometric properties for the measurement tools.

ES3 Rating of the psychometric properties of health-related quality of life assessment tools used in studies of treatment of diabetic retinopathy

Measure | Content validity | Construct validity | Internal consistency | Test re-test reliability | Measurement error | Responsiveness | Interpretability
SF-36 | + | + | + | + | + | + | +
VFQ-25 | + | + | + | + | 0 | ? | ?
VF-14 | ? | + | + | ? | 0 | ? | 0
DTSQ | + | + | + | + | + | + | 0
RetDQoL | + | + | + | 0 | 0 | 0 | 0
RetTSQ | + | + | + | 0 | 0 | 0 | 0

Method or result was rated as: + = high quality; ? = indeterminate; - = low quality; 0 = no data available

### Key Questions 2 and 3 What is the evidence that HRQL is improved by any intervention; and what is the relationship between HRQL and any relevant variables?

We identified two RCTs42,47 and seven observational studies that addressed Key Questions 2 and 3. Sample sizes ranged from 55 to 345 (IQR: 77 – 293.5). Both RCTs were multicenter trials that recruited patients in Australia, North and South America, Europe, India and Turkey. Both trials were assessed as having unclear risk of bias. The primary concern was incomplete reporting and the use of the last observation carried forward approach for missing data. Both trials received industry funding.

For the observational studies, the interventions included laser photocoagulation,48,54 vitrectomy,41,45,46 panretinal photocoagulation,46 and phacoemulsification cataract surgery for diabetic patients with cataracts.51,53 Two of the four cohort studies were of good quality, and all three before-after studies were of moderate to good quality. However, overall this collection of observational studies is at high risk of bias due to weak study designs (before-after and cohort studies). We conducted a post hoc analysis of the subgroup of patients with diabetic macular edema (DME). Six studies41,42,45,47,48,54 reported results for those with DME. Two studies51,53 included patients with DME, but did not report separate results. Patients with DME represented less than five percent of the study sample in these studies. One study46 did not report whether patients with DME were included in their study.

### Results

Anti-Vascular Endothelial Growth Factor (anti-VEGF). Two RCTs provided data (Table ES4). One RCT reported data on the administration of pegaptanib sodium versus sham injections—133 patients received 0.3 mg of pegaptanib sodium and 127 patients received a sham treatment. All patients were diagnosed with DME. The patients receiving pegaptanib sodium reported statistically significant improvements from baseline on the VFQ–25 domains for near vision activities, distance vision activities, and social functioning at 54 weeks compared with patients treated with a sham injection. There were no statistically significant differences for the other domains or for the composite score. At 102 weeks patients receiving pegaptanib sodium reported statistically significant improvements in the composite score and the domains for distance vision activities, social functioning, and mental health. One three-arm RCT reported data on the administration of ranibizumab with and without laser treatment—116 patients received 0.5 mg of ranibizumab plus sham laser, 118 patients received 0.5 mg of ranibizumab plus laser, and 111 patients received sham treatment plus laser. All patients were diagnosed with DME. The composite score and the scores on the domains for general vision, near vision activities, and distance activities of the VFQ–25 were significantly improved from baseline to 12 months for patients treated with ranibizumab alone, or in combination with laser treatment compared with patients with laser treatment only. The strength of evidence for anti-VEGF is low. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.

Table ES4 Study characteristics and outcomes for studies reporting the impact of interventions for diabetic retinopathy on HRQL

Author Year Study design Country | Intervention HRQL measure Followup | Participants | Visual acuity outcomes | HRQL outcomes
Anti-VEGF
Mitchell 2011^47^ RCT Multicenter (73 centers in Australia, Canada, Europe, Turkey) | G1—ranibizumab 0.5 mg + sham laser G2—ranibizumab 0.5 mg + laser G3—laser + sham injection VFQ-25 3 mo, 12 mo | G1 = 116 G2 = 118 G3 = 111 DME = 345 (100%) | Median change in BCVA from baseline to 12 mo: G1 = 6.1±6.43 G2 = 5.9±7.92 G3 = 0.8±8.59 Median change in BCVA from baseline to 12 mo: G1 = 6.1 (-10.9–25.2) G2 = 6.0 (-26.7–27.6) G3 = 1.3 (-37.8–26.8) 95% CI for the mean change: G1 = 4.9, 7.3 G2 = 4.4, 7.3 G3 = -0.8, 2.4 | VFQ-25, composite score at 12 mo G1—baseline: NR; improvement: 5.0 (p=0.014 compared to G3) G2—baseline: NR; improvement: 5.4 (p=0.004 compared to G3)) G3—baseline: NR; improvement: 0.6 (NR) Other domains: G1—significant improvement for general vision, near vision activities, distance activities; other domains: NR G2— significant improvement for general vision, near vision activities, distance activities; other domains: NR G3—baseline: NR; no significant change from baseline
Sultan 2011^42^ RCT Multicenter (60 centers in Australia, Europe, India, North America, South America) | G1—pegaptanib 0.3 mg G2—sham injection VFQ–25 baseline, 18, 54 & 102 wk | G1 = 133 G2 = 127 DME = 260 (100%) | % improvement of ≥10 letters from baseline at 54 wk: G1 = 43/133 (36.8%) G2 = 25/127 (19.7%) Odds ratio (95% CI) = 2.38 (1.32, 4.30); p=0.0047 % improvement of ≥10 letters from baseline at 102 wk G1 = 41/107 (38.3%) G2 = 30/100 (30%) Odds ratio (95% CI) = 1.57 (0.83, 2.97); p=0.1729 | VFQ-25, composite score at 54 wk: G1—70.4; improvement 4.5 G2—69.2; improvement 1.3 Between group differences—2.92; range - 0.32 to 6.16 (p = 0.077) VFQ-25, composite score at 102 wk (n = 207): G1—69.8; improvement 4.6 G2—66.2; improvement 0.1 Between group differences—4.47; range - 0.26 to 8.68 (p = 0.038) Other domains: 54 wk: G1 vs. G2 had significantly more improvement for near vision activities, distance activities, social functioning; no difference for other domains 102 wk: G1 vs. G2 had significantly more improvement for distance activities, social functioning, mental health; no difference for other domains
Laser photocoagulation
Tranos 2004^48^ Before-after United Kingdom | Laser photocoagulation VFQ–51 3 mo | DME = 55 (100%) Mild NPDR = 13 Moderate NPDR = 32 Severe NPDR = 10 | Binocular vision—baseline: 48.7±6.7 Distance vision—baseline: 42.7±8.4 letters; improvement: 2.2±6.2 Near vision—baseline: 56.4±9.1 letters; improvement: 2.1±5.0 | Composite score—baseline: 77.9±17.6; improvement: 4.9±8.9 (p<0.001); Subscales—statistically significant improvement on 8 of 11 vision-related domains
Mozaffarieh 2005b54 Before-after Austria | Laser photocoagulation DTSQ 9 mo | Total = 105 PDR = 56 (53%) DME = 49 (47%) | 24.7% reported improvement in visual acuity; 71.4% were unchanged; 3.8% were worse No difference in improvement between patients with PDR or DME | Mean± SD = 27.9±5.2 (maximum possible score = 36)
Vitrectomy
Emi 2008^45^ Before-after Japan | Vitrectomy VFQ–25 (Japanese version) 6 mo | DR = 87 (total) G1—vitreous hemorrhage = 41 G2—DME = 28 G3—fibrovascular membrane = 18 | G1—improved: 35; unchanged: 4; worse: 2 G2—improved: 9; unchanged: 16; worse: 3 G3—improved: 13; unchanged: 3; worse: 2 | G1—statistically significant improvement on 10 of 12 subscales G2—no statistically significant change from baseline on any subscales G3—only the general vision subscale had a statistically significant improvement from baseline
Okamoto 2010^41^ Prospective cohort Japan | Pars plana vitrectomy VFQ–25 (Japanese version) 3 mo | G1—PDR = 99 G2—DME = 38 G3—normal controls = 100 Note: this is part of a larger study (n = 399) of patients with vitreoretinal disorders—retinal vein occlusion (32), macular hole (42), epiretinal membrane (33), retinal detachment (55) | logMAR G1—baseline: 1.37±0.75; 3 mo: 0.53±0.62 (p < 0.0001) G2—baseline = 0.76±0.49; 3 mo: 0.55±0.51 (p < 0.01) Contrast sensitivity G1—baseline: 5.4±7.2; 3 mo: 14.0±7.9 (p < 0.0001) G2—baseline 9.2±6.5; 3 mo: 12.7±7.1 (p < 0.0001) | G1—baseline: 52.8±19.0; 3 mo: 63.6±17.5 (p <0.001); Subscales—statistically significant improvement on 9/11 vision-related domains G2—baseline: 53.0±20.5; 3 mo: 59.0±21.0 (p = 0.84); Subscales—statistically significant improvement on 4/11 vision-related domains G3—85.0±9.1
Vitrectomy and panretinal photocoagulation
Emi 2009^46^ Prospective cohort Japan | G1—vitrectomy G2—panretinal photocoagulation G3—no treatment VFQ–25 (Japanese version) 1 yr | G1 = 136 G2 = 60 G3 = 131 | logMAR—right eye G1—baseline: 0.21; 1 yr: 0.46 (p < 0.001) G2—baseline: 0.64; 1 yr: 0.52 (p = 0.272) G3—baseline: 1.09; 1 yr: 1.06 (p = 0.294) logMAR—left eye G1—baseline: 0.19; 1 yr: 0.38 (p < 0.001) G2—baseline: 0.61; 1 yr: 0.56 (p = 0.081) G3—baseline: 1.10; 1 yr: 1.09 (p = 0.704) | Composite score G1—baseline: 67.4±17.3; 1 yr: 75.4±17.5 (p<0.001) G2—baseline: 80.7±15.7; 1 yr: 77.6±19.1 (p=0.113) G3—baseline: 91.3±7.8; 1 yr: 92.2±7.8 (p=0.169)
Phacoemulsification cataract surgery
Mozaffarieh 2005a53 Prospective cohort Austria | Phacoemulsification cataract surgery VF–14 3 mo | Cataracts = 67 (total) G1—no DR = 17 G2—mild NPDR = 19 G3—moderate/severe NPDR = 16 G4—PDR = 15 | logMAR (range) G1—baseline: 0.62 (0.30–1.30); improvement 0.55 (0.30–1.15) G2—baseline: 0.60 (0.30–1.30); improvement 0.50 (0.30–1.08) G3—baseline: 0.67 (0.30–1.30); improvement 0.26 (0.15–0.48) G4—baseline: 0.71 (0.40–1.30); improvement 0.15 (-0.70–0.60) | G1—baseline: 52.21 (32.14–78.57); improvement 42.33 (21.43–60.71) G2—baseline: 55.92 (30.36–85.71); improvement 36.00 (12.50–58.93) G3—baseline: 46.65 (30.36–64.29); improvement 9.26 (1.79–25.00) G4—baseline: 40.12 (25.00–67.86); improvement 5.00 (-25.00–25.00)
Mozaffarieh 2009^51^ Prospective cohort Austria | Phacoemulsification cataract surgery G1—first-eye surgery G2—both eyes VF–14 12 mo | Cataracts = 89 (total) No DR = 23 Mild NPDR = 23 Moderate NPDR = 22 PDR = 21 | G1 & G2—patients with no or mild NPDR had greater improvement in visual acuity | G1 baseline: no DR: 59.3±12.4; mild 39.3±5.2; severe 40.9±8.6; PDR 35.3±4.4 6 mo: no DR: 96.8±2.0; mild 86.5±13.6; severe 48.8±6.7; PDR 37.9±14.0 12 mo: no DR: 79.5±5.5; mild 72.2±8.3; severe 46.1±10.7; PDR 39.9±9.0 G2 baseline: no DR 46.8±8.7; mild 63.4±16.3; severe 54.6±8.8; PDR 50.6±11.4 6 mo: no DR: 93.0±4.3; mild 94.6±2.5; severe 60.9±6.6; PDR 53.0±10.9 12 mo: no DR: 95.3±1.9; mild 95.3±2.2; severe 47.8±16.0; PDR 47.6±15.0

95% CI = 95 percent confidence interval; BCVA = best corrected visual acuity; DR = diabetic retinopathy; DTSQ = Diabetes Treatment Satisfaction Questionnaire; DME = diabetic macular edema; mg = milligram; mo = month; NPDR = nonproliferative diabetic retinopathy; PDR = proliferative diabetic retinopathy; VF–14 = Visual Function–14; VFQ = National Eye Institute Visual Function Questionnaire; wk = week; yr = year

Laser photocoagulation. Two before-after studies provided data (Table ES4). In one study, 105 patients with PDR and DME reported high scores on the DTSQ at 9 months following surgery. Results were not reported separately for the two groups of patients. In the second study, 55 patients with DME reported a statistically significant improvement in HRQL at 3 months following surgery. While HRQL improved following laser photocoagulation, the strength of evidence is insufficient to draw conclusions about the effect of laser photocoagulation on HRQL.

Vitrectomy. One cohort study and one before-after study provided data (Table ES4). In the prospective cohort study, 99 patients with PDR reported a statistically significant improvement on the VFQ–25 (Japanese version) at 3 months following surgery. For those with DME (n = 38), the score improved, but the change was not statistically significant. The score on the VFQ–25 for the normal control group was statiscally significantly higher than the preoperative and postoperative scores of patients with PDR and DME.

In the before-after study, 41 patients with vitreous hemorrhage reported statistically significant improvements on the VFQ–25 (Japanese version) at 6 months following surgery. This contrasts with patients with DME (n = 28) who reported no significant change in HRQL and fibrovascular membrane (n = 18) who only reported a statistically significant change on the general vision subscale. While HRQL improved for some subgroups of patients with DR following vitrectomy, the strength of evidence is insufficient to draw conclusions about the effect of vitrectomy on HRQL.

Vitrectomy and panretinal photocoagulation. One cohort study (Table ES4) provided data for 327 patients with DR. Of these, 136 underwent vitrectomy, 60 received panretinal photocoagulation, and 131 had no treatment and served as a comparison group. For the vitrectomy group, there was a statistically significant improvement in the VFQ–25 (Japanese version) composite score at 1 year following surgery. Changes in the VFQ–25 scores for the comparison group and the photocoagulation group were not statistically significant. The strength of evidence is insufficient to draw conclusions about the relative effect of vitrectomy versus panretinal photocoagulation on HRQL.

Phacoemulsifcation. Two cohort studies provided data (Table ES4). One study evaluated visual outcomes and visual function using the VF–14 after first-eye phacoemulsification cataract surgery. Three months following surgery, 94 percent of patients reported improved visual acuity, and 93 percent reported improvements in visual function. Patients with no DR or mild retinopathy demonstrated significantly greater improvements in visual acuity and visual function compared with patients with more advanced DR.

The second study followed 89 diabetic patients with bilateral cataracts. At 12 months following surgery, patients with PDR had the lowest VF–14 scores at baseline and improved marginally over the study period regardless of whether they had cataract surgery on one or both eyes. A similar pattern was seen for patients with moderate or severe NPDR. For patients with no or mild NPDR, maximum VF–14 scores at 12 months were significantly higher than for patients with more severe DR.

The impact of first-eye cataract surgery on QOL was evident in patients with no or mild DR with the highest VF–14 scores being achieved by 91 percent of patients in the first month. In contrast, for those with more severe DR, 79 percent achieved the highest VF–14 score after 3 months. In patients with no or mild DR who underwent second-eye surgery the improved functional status achieved after first surgery was sustained. For those who did not have second- eye surgery, VF–14 scores decreased after 8 and 12 months. While HRQL improved following phacoemulsification cataract surgery, the strength of evidence is insufficient to draw conclusions about the effect of this surgery on HRQL.

Factors associated with outcomes. No conclusions can be drawn about factors associated with HRQL outcomes. In one study, multivariate analysis found that age <65 years, more severe level of DR, and low preoperative QOL were associated with improved HRQL following laser photocoagulation. In another study that also investigated laser photocoagulation, univariate analysis showed an association between age and treatment satisfaction, with older patients (>65 years) being more satisfied.

In a study that looked at vitrectomy, multivariate analysis showed that improvement in contrast sensitivity was significantly correlated with changes in the VFQ–25 composite score for patients with PDR and DME. There was no significant correlation between VFQ–25 and visual acuity.

## Discussion

Using a comprehensive search strategy and concerted efforts to avoid publication and selection bias, this review identified the evidence on the effect that interventions for DR, including DME have on HRQL. Overall we identified four measures—one generic, two vision- specific, and one diabetes-specific—that have been used to measure HRQL in studies of treatment for DR. As well, we identified two recently developed tools that are specific to patients with DR. We identified two RCTs and seven observational studies involving between 55 and 345 patients that addressed the question of whether HRQL is improved for any intervention for DR.

### HRQL Measures

Only one generic HRQL measure has been used to assess the impact that interventions for DR have on HRQL. The SF–36 gathers information about the patient's perceived health and asks about eight health concepts: physical functioning, physical role functioning, bodily pain, general health, vitality, social function, emotional role functioning, and mental health. Generic HRQL tools are generally insensitive to the presence of specific eye disease. Furthermore, the SF–36 appears to be unresponsive to changes in visual acuity in patients with DR.49 The authors suggest that this may be because the SF–36 assesses a wide range of characteristics that are not directly related to visual acuity. While the SF–36 is a reasonable choice for researchers to consider if a generic health status measure is needed, other generic measures that include assessment of vision function (e.g., the Health Utilities Index76) may be worth consideration for this patient population. Generic HRQL tools can be used to make comparisons with the general population (regardless of the underlying condition), and to estimate the relative impact of various medical conditions.20,23,49 The decision to use a generic measure along with a specific measure needs to be driven by the purpose of the measurement.35

Two validated and clinically responsive vision-specific measures, the VFQ–25 and VF–14, have been used to measure the impact of different interventions on HRQL in individuals with DR. Vision-specific measures have been shown to be sensitive to differences in vision status and functioning among patients with DR.50,63,64,66

The diabetes-specific tool, the DTSQ, was specifically developed to measure satisfaction with treatment regimens in individuals with diabetes. Research has shown that satisfaction with treatment is associated with compliance with treatment.77,78 The DTSQ was not designed to measure satisfaction with other aspects of the diabetes care and management.67 It is most useful when used as one of a profile of tools to assess other important outcomes, including QOL or HRQL.

We identified two disease-specific measures developed specifically for patients with DR – the RetDQoL and the RetTSQ. The tools have been developed in parallel, and to date, are the only measures that assess the impact of DR on different aspects of QOL. Unlike other tools identified in this review, the RetDQoL and RetTSQ have been designed to enable patients to consider specifically the impact of diabetic eye problems and their treatment, rather than health generally, vision or vision loss, or impact of diabetes.18 Preliminary psychometric testing appears promising for content validity and internal consistency. Additional testing is ongoing to assess test-retest reliability, responsiveness, and interpretability.

Despite the availability of reliable and valid tools to measure HRQL,20,28,35 our review identified several studies that used questions or tools whose psychometric properties have not been evaluated. In order to provide meaningful HRQL data, it is crucial that the measurement tools are reliable, valid, and responsive (i.e., sensitive to change). In this way, researchers, clinicians, and patients will be better able to assess and interpret the impact of different interventions on HRQL outcomes.

### Impact of interventions on HRQL

To date, two RCTs have reported HRQL outcomes.42,47 More are expected as a search of Clinicaltrials.gov identified 13 ongoing or recently completed trials investigating interventions for DME or DR that indicate the intention to report HRQL outcomes. The PKC-DRS2 trial of once-daily ruboxistaurin versus placebo measured HRQL using the SF–36 and the VFQ–25;^75^ however, results for the HRQL outcomes have not been reported. Futhermore, preliminary results from the RISE and RIDE trials79 comparing ranibizumab versus sham have been presented at national meetings; however, to date, the final results for HRQL have not been published.

In general, it appears that HRQL outcomes improve following various interventions to treat DR at different levels of severity. For anti-VEGF to treat patients with DME, two RCTs with unclear risk of bias found statistically significant improvements in some domains of the VFQ–25; however, the results were not consistent at 1 year post-treatment. We concluded that the strength of evidence was low.

For other interventions, the results are based on one or two observational studies with a high risk of bias. Therefore, we conclude that the strength of evidence is insufficient to draw any conclusions about which of these interventions for DR are effective in improving HRQL. Furthermore, there is a concern about the applicability of the results of the observational studies to patients in North America. All of these studies were conducted in Europe or Japan. In particular, the three studies that were based in Japan used the Japanese version of the VFQ–25.

This review shows that the impact of interventions for DR on HRQL has not been adequately assessed in the current literature. Research has increasingly highlighted HRQL as an important health outcome in diabetes.35 Diabetic patients with retinopathy have reported that vision loss impacts multiple areas of well-being including: independence, mobility, leisure, and self- care.7,17,18 However, the impact of DR is due not only to impaired vision, but also the emotional reaction to diagnosis and treatment, anxiety about the future, and advice to restrict physical activities.18 For researchers and clinicians conducting trials of interventions for DR, the inclusion of HRQL outcomes will provide a better understanding how DR and its treatment affects outcomes that are important to patients.

### Recommendations for Future Research

- RCTs are needed to assess the impact of interventions for DR, including DME on HRQL. All RCTs investigating the effectiveness of interventions for DR should measure and report pre- and post-treatment HRQL outcomes.
- Currently, there are a number of ongoing or recently completed trials that reported the intention to capture HRQL outcomes. Future systematic reviews on this topic should followup on these studies and incorporate their findings, if appropriate.
- Researchers should use valid and reliable HRQL tools whose psychometric properties have been evaluated and reported.
- Ongoing assessment of the psychometric properties of the DR specific tools is encouraged.
- Patients should be followed for at least 6 months post-intervention in order to capture maximum improvement for visual acuity.
- Researchers should use standard protocols to assess visual acuity to allow for comparison across trials
- RCTs should be designed and conducted to minimize risk of bias where at all possible. Authors may find tools such as the CONSORT18,76 statement helpful in designing and reporting on RCTs.

## Conclusions

We identified four HRQL measurement instruments that have been used to assess the impact of treatment in patients with DR. The psychometric properties of these tools have been adequately evaluated. Two tools developed specifically for patients with DR are currently undergoing evaluation. In general, HRQL was improved following interventions for DR. Further research on HRQL following anti-VEGF treatment for DME is needed to confirm the results of two RCTs. The current research on the impact of other interventions for DR on HRQL is insufficient to draw conclusions about the relative effect of one intervention versus another. RCTs that assess the impact of treatments for DR should include HRQL as an outcome.