# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Jerry Cavallerano
  Department of Ophthalmology, Harvard Medical School,
  Beetham Eye Institute, Joslin Diabetes Center
  Boston, Massachusetts
- Theodore Leng
  Clinical Assistant Professor
  Byers Eye Institute at Stanford
  Palo Alto, California
- Deborah Wexler
  Assistant Professor
  MGH and Harvard Medical School
  Boston, Massachusetts
- Ingrid Zimmer-Galler
  Associate Professor
  Johns Hopkins Wilmer Eye Institute
  Baltimore, Maryland