# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Kenneth Bond for the protocol development and level one screening, Kelly Russell for level one and level two screening, Elizabeth Sumamo for level one and level two screening, Christine Ha for data abstraction and verification, Carol Spooner for quality assessment, Annabritt Chisholm for article retrieval, and Jennifer Seida for copyediting.