# Discussion

Using a comprehensive search strategy and concerted efforts to avoid publication and selection bias, this review identified the evidence on the effect that interventions for DR or DME have on HRQL. Overall we identified four measures—one generic, two vision-specific, and one diabetes-specific—that have been used to measure HRQL in studies of treatment for DR. As well, we identified two recently developed tools that are specific to patients with DR. We identified two RCTs and seven observational studies involving between 55 and 345 patients that addressed the question of whether HRQL is improved for any intervention for DR or DME.

## HRQL Measures

Only one generic HRQL measure has been used to assess the impact that interventions for DR have on HRQL in patients with DR. The SF–36 gathers information about the patient's perceived health and asks about eight health concepts: physical functioning (ability to perform physical activities), physical role functioning (problems with daily tasks due to physical health), bodily pain (degree of limitation due to pain), general health (personal perception of health), vitality (degree of energy—tired and worn out to full of energy), social function (ability to perform social activities), emotional role functioning (problems with daily tasks due to mental health), and mental health (overall emotional state).50 Generic HRQL tools are generally insensitive to the presence of specific eye disease. Furthermore, the SF–36 appears to be unresponsive to changes in visual acuity in patients with DR.49 The authors suggest that this may be because the SF–36 assesses a wide range of characteristics that are not directly related to visual acuity. Other generic measures that include assessment of vision function (e.g., the Health Utilities Index76) may be a reasonable choice for researchers to consider if a generic health status measure is needed. Generic HRQL tools can be used to make comparisons with the general population (regardless of the underlying condition), estimate the relative impact of various medical conditions, and derive a utility value summarizing health status for cost-effectiveness modeling.20,23,49 The decision to use a generic measure along with a specific measure needs to be driven by the purpose of the measurement.35

Two validated and clinically responsive vision-specific measures, the VFQ–25 and VF–14, have been used to measure the impact of different interventions on HRQL in individuals with DR. Vision-specific measures have been shown to be sensitive to differences in vision status and functioning among patients with DR.50,63,64,66

The diabetes-specific tool, the DTSQ, was specifically developed to measure satisfaction with treatment regimens in individuals with diabetes. Research has shown that satisfaction with treatment is associated with compliance with treatment.77,78 The DTSQ was not designed to measure satisfaction with other aspects of the diabetes care and management.67 It is most useful when used as one of a profile of tools to assess other important outcomes, including quality of life (QOL) or HRQL.

We identified two disease-specific measures developed specifically for patients with DR—the Diabetic Retinopathy Dependent Quality of Life (RetDQoL) and the Diabetic Retinopathy Treatment Satisfaction Questionnaire (RetTSQ). The tools have been developed in parallel, and to date, are the only measures that assess the impact of DR on different aspects of QOL. Unlike other tools identified in this review, the RetDQoL and RetTSQ have been designed to enable patients to consider specifically the impact of diabetic eye problems and their treatment, rather than health generally, vision or vision loss, or impact of diabetes.18 Preliminary psychometric testing appears promising for content validity and reliability. Additional testing is ongoing to assess responsiveness and interpretability.

Despite the availability of reliable and valid tools to measure HRQL,20,28,35 our review identified several studies that used questions or tools whose psychometric properties had not been evaluated. In order to provide meaningful HRQL data, it is crucial that the measurement tools are reliable, valid, and responsive (i.e., sensitive to change). In this way, researchers, clinicians, and patients will be better able to assess and interpret the impact of different interventions for DR on HRQL outcomes.

## Impact of interventions on HRQL

To date, two RCTs have reported HRQL outcomes.42,47 More are expected as a search of Clinicaltrails.gov (https://clinicaltrials.gov/) identified 13 ongoing or recently completed trials investigating interventions for DME or DR that indicate the intention to report HRQL outcomes. The PKC-DRS2 trial of once-daily ruboxistaurin versus placebo measured HRQL using the SF–36 and the VFQ–25;^75^ however, results for the HRQL outcomes have not been reported. Furthermore preliminary results from the RISE and RIDE trials79 comparing ranibizumab versus sham have been presented at national meetings; however, to date, the final results for HRQL have not been published.

In general, it appears that HRQL outcomes improve following various interventions to treat DR at different levels of severity. For anti-VEGF to treat patients with DME, two RCTs with unclear risk of bias found statistically significant improvements in some domains of the VFQ–25; however, the results were not consistent at 1 year post-treatment. We concluded that the strength of evidence was low.

For other interventions, the results are based on one or two observational studies with a high risk of bias. Therefore, we conclude that the strength of evidence is insufficient to draw any conclusions about which of these interventions for DR are effective in improving HRQL. Furthermore, there is a concern about the applicability of the results of the observational studies to patients in North America. All of these studies were conducted in Europe or Japan. In particular, the three studies that were based in Japan used the Japanese version of the VFQ–25.

This review shows that the impact of interventions for DR on HRQL has not been adequately assessed in the current literature. Research has increasingly highlighted HRQL as an important health outcome in diabetes.35 Diabetic patients with retinopathy have reported that vision loss impacts multiple areas of well-being including: independence, mobility, leisure, and self-care.7,17,18 However, the impact is due not only to impaired vision, but also the emotional reaction to diagnosis and treatment, anxiety about the future, and advice to restrict physical activities.18 For researchers and clinicians conducting trials of interventions for DR, the inclusion of HRQL outcomes will provide a better understanding how DR and its treatment affects outcomes that are important to patients.

## Recommendations for Future Research

- RCTs are needed to assess the effectiveness of interventions for DR, including DME to improve HRQL. All RCTs investigating the effectiveness of interventions for DR should measure and report pre- and post-treatment HRQL outcomes.
- Currently, there are a number of ongoing or recently completed trials that reported the intention to capture HRQL outcomes. Future systematic reviews should followup on these studies and incorporate their findings, if appropriate.
- Researchers should use valid and reliable HRQL tools whose psychometric properties have been evaluated and reported.
- Ongoing assessment of psychometric properties of the DR specific tools is encouraged.
- Patients should be followed for at least 6 months post-intervention in order to capture maximum improvement for visual acuity.
- Use standard protocols to assess visual acuity to allow for comparison across trials
- RCTs should be designed and conducted to minimize risk of bias where at all possible. Authors may find tools such as the CONSORT18,80 statement helpful in designing and reporting on RCTs.

## Conclusions

We identified four HRQL measurement instruments that have been used to assess the impact of treatment in patients with DR. The psychometric properties of these tools have been adequately evaluated. Two tools developed specifically for patients with DR are currently undergoing evaluation. In general, HRQL was improved following interventions for DR and DME. Further research on HRQL following anti-VEGF treatment for DME is needed to confirm the results of two RCTs. The current research on the impact of other interventions for DR on HRQL is insufficient to draw conclusions about the relative effect of one intervention versus another. RCTs that assess the impact of treatments for DR should include HRQL as an outcome.