# Appendix E Sample HRQL assessment tools

Generic HRQL assessment tools:

Your Health and Well-Being

Low vision-related HRQL assessment tools:

National Eye Institute Visual Functioning Questionnaire - 25 (VFQ-25)

Visual Function—14 Questionnaire