# Appendix C Excluded Studies

482 studies were excluded from the review. Reasons for exclusion include: publication type (n=78), age being less than 18 years (n=3), diagnosis without DR (n=117), intervention (n=99), outcomes (n=185).

## Publication type (n = 78)

1 (2003). Diabetic retinopathy on a new scale. J Am Optom Assoc.
2 (2007). The aging retina: diseases of the retina. Insight.
3 (2007). Assessing care of vulnerable elders-3 quality indicators. J Am Geriatr Soc.
4 (2009). Ophthalmic inserts shown to improve dry eye symptoms, quality of life. Ocular Surgery News.
5 Abbaszadeh AS, Tabatabaei MO, Pajouhi M. (2009). Diabetes in old age, a review. Iran J Diabetes Lipid Disord.
6 Averbukh E, Banin E. (2006). Diabetic macular edema: towards therapy aimed at the underlying pathogenic mechanisms. Isr Med Assoc J.
7 Baker RS. (2003). Diabetic retinopathy in African Americans: vision impairment, prevalence, incidence, and risk factors. Int Ophthalmol Clin.
8 Balcer LJ. (2006). Optic neuritis. New Engl J Med.
9 Bernstein RK. (1993). Depression in adults with diabetes. Diabetes Care.
10 Brown CM, Wong EYH, O'Connor PM, et al. (2009). Measurement of quality of life for people with diabetic retinopathy impairment. Expert Rev Ophthalmol.
11 Caditz J. (1992). An education-support-group program for visually impaired people with diabetes. J Vis Impairm Blindn.
12 Carney C. (1998). Diabetes mellitus and major depressive disorder: an overview of prevalence, complications, and treatment. Depress Anxiety.
13 Cheah JS, Lim P. (1980). Diabetic retinopathy and metabolic control. Ann Acad Med Singapore.
14 Cherner R. (1997). Help for the sight-impaired diabetic patient. Consultant (00107069).
15 Cherner R. (1997). Primary care update. Help for the sight-impaired diabetic patient. Consultant (00107069).
16 Chew EY. (2003). A simplified diabetic retinopathy scale. Ophthalmology.
17 Chipkin SR, Klugh SA, Chasan-Taber L. (2001). Exercise and diabetes. Cardiol Clin.
18 Cleary ME. (1985). Aiding the person who is visually impaired from diabetes. Diabetes Educ.
19 Consoli A, Gomis R, Halimi S, et al. (2004). Initiating oral glucose-lowering therapy with metformin in type 2 diabetic patients: an evidence-based strategy to reduce the burden of late-developing diabetes complications. Diabetes Metab.
20 Dineen B, Waldron-Lynch F, Harney F, et al. (2008). Laser photocoagulation for diabetic retinopathy. Cochrane Database of Syst Rev.
21 Donohue B, Acierno R, Hersen M, et al. (1995). Social skills training for depressed, visually impaired older adults. A treatment manual. Behav Modif.
22 Eastman R. (1996). Cost-effectiveness of detecting and treating diabetic retinopathy…. Diabetes Spectr.
23 Falavarjani KG, Modarres M, Nazari H, et al. (2010). Diabetic macular edema following panretinal photocoagulation. Arch Ophthalmol.
24 Fenwick EK, Pesudovs K, Rees G, et al. (2011). The impact of diabetic retinopathy: understanding the patient's perspective. Br J Ophthalmol.
25 Frank RN. (2011). Importance of the NHANES 2005-2008 diabetic: Retinopathy data. Arch Ophthalmol.
26 Gardner TW. (2011). The restore study: Ranibizumab monotherapy or combined with laser versus laser monotherapy for diabetic macular edema. Evidence-Based Ophthalmology.
27 Garg MK, Baliga KV. (2002). Management of type 2 diabetes (NIDDM). Med J Armed Forces India.
28 Gill G. (1991). Psychological aspects of diabetes. Br J Hosp Med.
29 Gillibrand W, Holdich P. (2010). Evidence-based management 20 assessment of retinopathy. Pract Nurs.
30 Gonder-Frederick LA, Cox DJ, Ritterband LM. (2002). Diabetes and behavioral medicine: the second decade. J Consult Clin Psychol.
31 Graham C, Lasko-McCarthey P. (1990). Exercise options for persons with diabetic complications. Diabetes Educ.
32 Grigorian RA, Castellarin A, Bhagat N, et al. (2003). Use of viscodissection and silicone oil in vitrectomy for severe diabetic retinopathy. Semin Ophthalmol.
33 Guerra CE, Datto CJ, Kim KH, et al. (2004). Quality of life instrument and retinal diseases. Ophthalmology.
34 Harper-Jaques S. (2004). Diabetes under control: diabetes and depression. Am J Nurs.
35 Hart J. (2006). Diabetes and complementary therapies: research review and clinical applications. Altern Complement Therap.
36 Henzen C. (2006). The diabetic--a difficult patient difficult to treat?. Praxis.
37 Herpertz S, Petrak F, Albus C, et al. (2003). Evidence-based diabetes guidelines of the German diabetes society: psychosocial factors and diabetes mellitus. Diabetes Stoffwechsel.
38 Horowitz A. (2003). Depression and vision and hearing impairments in later life. Generations.
39 Horowitz A, Reinhardt JP. (2006). Adequacy of the mental health system in meeting the needs of adults who are visually impaired. J Vis Impair Blind.
40 Jacobson AM. (1996). The psychological care of patients with insulin-dependent diabetes mellitus. New Engl J Med.
41 Jindal K, MacNair L, Senior P. (2005). A collaborative approach to diabetes nephropathy prevention. Alberta RN.
42 Katon WJ. (2008). The comorbidity of diabetes mellitus and depression. Am J Med.
43 Kieffer KM, Reese RJ. (2002). A reliability generalization study of the geriatric depression scale. Educ Psychol Meas.
44 Mendrinos E, Donati G, Pournaras CJ. (2009). Rapid and persistent regression of severe new vessels on the disc in proliferative diabetic retinopathy after a single intravitreal injection of pegaptanib. Acta Opthalmologica.
45 Merrill JL. (1993). Support groups for persons with diabetes and visual impairment. J Vis Impair Blind.
46 Montez JK, Karner TX. (2005). Understanding the diabetic body-self. Qual Health Res.
47 Norris SL. (2005). Health-related quality of life among adults with diabetes. Curr Diabetes Rep.
48 Norris SL, Kansagara D, Bougatsos C, et al. (2008). Screening adults for type 2 diabetes: A review of the evidence for the U.S. preventive services task force. Ann Intern Med.
49 Oehler-Giarratana J. (1978). Meeting the psychosocial and rehabilitative needs of the visually impaired diabetic. J Vis Impair Blind.
50 Orr AL, Huebner KM. (2001). Toward a collaborative working relationship among vision rehabilitation and allied health professionals. J Vis Impair Blind.
51 Orticio LP. (2007). Measuring health-related quality of life among older visually impaired adults: a preview to instrument construction. Insight.
52 Paulus YM, Gariano RF. (2009). Diabetic retinopathy: a growing concern in an aging population. Geriatrics.
53 Pompei P. (2006). Diabetes mellitus in later life. Generations.
54 Porta M, Bandello F. (2002). Diabetic retinopathy: a clinical update. Diabetologia.
55 Pouwer F, Hermanns N. (2009). Insulin therapy and quality of life. A review. Diabetes Metab Res Rev.
56 Prasad S. (1999). Survey of diabetic retinopathy screening services in England and Wales. Diabet Med.
57 Rao PM. (2008). Diabetic retinopathy: new proposed classification. Indian J Ophthalmol.
58 Raphael BA, Galetta KM, Jacobs DA. (2007). Validation and test characteristics of a 10-item neuro-ophthalmic supplement to the NEI-VFQ-25. Rev Neurol Dis.
59 Robertson C. (1989). Coping with chronic complications… diabetes. RN.
60 Rosenthal AR. (1990). Failing sight. Br Med J.
61 Rosenthal MJ. (2004). Analyses of nursing home residents with diabetes at admission. J Am Med Dir Assoc.
62 Rubin RR, Ciechanowski P, Egede LE, et al. (2004). Recognizing and treating depression in patients with diabetes. Curr Diabetes Rep.
63 Sahu AK, Majji AB. (2010). Effect of ruboxistaurin on the visual acuity decline associated with long-standing diabetic macular edema. Invest Ophthalmol Vis Sci.
64 Servat JJ, Risco M, Nakasato YR, et al. (2011). Visual impairment in the elderly: Impact on functional ability and quality of life. Clin Geriatr.
65 Shotliff K, Balasanthiran A. (2009). Diabetic retinopathy and eye screening. Pract Nurs.
66 Smiddy WE, Flynn J. (1999). Vitrectomy in the management of diabetic retinopathy. Surv Ophthalmol.
67 Sokol-McKay D, Buskirk K, Whittaker P. (2003). Adaptive low-vision and blindness techniques for blood glucose monitoring. Diabetes Educ.
68 Strachan MWJ. (2005). Fear of diabetes complications. Diabetes Metab Res Rev.
69 Taylor HR. (2005). Diabetic retinopathy. Clin Exp Ophthalmol.
70 Ting JH, Martin DK. (2006). Basic and clinical aspects of gene therapy for retinopathy induced by diabetes. Curr Gene Ther.
71 Torrance GW. (1987). Utility approach to measuring health-related quality of life. J Chronic Dis.
72 Van Den Bosch-De Haeselaer. (2003). Quality of life of the diabetic. Louvain Med.
73 Vijan S, Hofer TP, Hayward RA. (2001). Cost-utility analysis of screening intervals for diabetic retinopathy in patients with type 2 diabetes mellitus. Clin Cornerstone.
74 Williams AS, Ponchillia SV. (1998). Psychosocial sequelae of visual loss in diabetes. Diabetes Educ.
75 Wroe J. (2005). Spring 2005 Meeting of the Association of British Clinical Diabetologists. Pract Diabetes Int.
76 Yamada Y, Takasawa T, Hirasawa Y, et al. (1999). Vision rehabilitation for the once-sighted blind report 5-Present condition and problems in communication and activities of daily living. Folia Ophthalmol Jpn.
77 Yospaiboon Y, Ratanapakorn T. (2007). Pars plana vitrectomy for diabetic macular edema. Cochrane Database of Syst Rev.
78 Zhang HW, Zhang H, Wan X, et al. (2009). Herbal medicine for diabetic retinopathy. Cochrane Database of Syst Rev.

## Age <18 yr (n = 3)

1 Hassan K, Loar R, Anderson BJ, et al. (2006). The role of socioeconomic status, depression, quality of life, and glycemic control in type 1 diabetes mellitus. J Pediatr.
2 Nicolucci A, Maione A, Franciosi M, et al. (2008). Quality of life and treatment satisfaction in adults with Type 1 diabetes: A comparison between continuous subcutaneous insulin infusion and multiple daily injections. Diabet Med.
3 Strohmeier SM, Back M, Egger JW, et al. (1998). Expectations concerning future life and late complications by adolescents and young adults with type 1 diabetes. Diabetes Stoffwechsel.

## Diagnosis without DR (n = 117)

1 (1985). Leads from the MMWR. Improving eye care for persons with diabetes mellitus--Michigan. JAMA.
2 (1996). Influence of intensive diabetes treatment on quality-of-life outcomes in the diabetes control and complications trial. Diabetes Care.
3 (2005). In brief. Program helps relieve distress of age-related eye disease. Harvard Women's Health Watch.
4 Abramoff MD, Suttorp-Schulten MS. (2005). Web-based screening for diabetic retinopathy in a primary care population: the EyeCheck project. Telemedicine Journal & E-Health.
5 Ahmadian L, Massof R. (2008). Does functional vision behave differently in low-vision patients with diabetic retinopathy?--A case-matched study. Invest Ophthalmol Vis Sci.
6 Alabraba V, Farnsworth A, Leigh R, Dodson P, et al. (2009). Exubera inhaled insulin in patients with type 1 and type 2 diabetes: the first 12 months. Diabetes Technol Ther.
7 Allen EM, Ziada HM, O'Halloran D, Clerehugh V, et al. (2008). Attitudes, awareness and oral health-related quality of life in patients with diabetes. J Oral Rehabil.
8 Bergh AL, Persson LO, Attvall S. (2000). Psychometric properties of the Swedish version of the Well +ó-Being Questionnaire in a sample of patients with diabetes type 1. Scand J Public Health.
9 Bonanomi MT, Nicoletti AG, Carricondo PC, Buzalaf F, et al. (2006). Retinal thickness assessed by optical coherence tomography (OCT) in pseudophakic macular edema. Arq Bras Oftalmol.
10 Bond GE, Burr RL, Wolf FM, Feldt K. (2010). The effects of a web-based intervention on psychosocial well-being among adults aged 60 and older with diabetes: A randomized trial. Diabetes Educ.
11 Brandle M, Davidson MB, Schriger DL, Lorber B, et al. (2003). Cost effectiveness of statin therapy for the primary prevention of major coronary events in individuals with type 2 diabetes. Diabetes Care.
12 Broman AT, Munoz B, Rodriguez J, Sanchez R, et al. (2002). The impact of visual impairment and eye disease on vision-related quality of life in a Mexican-American population: proyecto VER. Invest Ophthalmol Vis Sci.
13 Cacciatore F, Abete P, Maggi S, Luchetti G, et al. (2004). Disability and 6-year mortality in elderly population. Role of visual impairment. Aging Clin Exp Res.
14 Camacho F, Anderson RT, Bell RA, Goff J, et al. (2002). Investigating correlates of health related quality of life in a low-income sample of patients with diabetes. Qual Life Res.
15 Chen JY, Diamant AL, Thind A, Maly RC. (2008). Determinants of breast cancer knowledge among newly diagnosed, low-income, medically underserved women with breast cancer. Cancer.
16 Chia EM, Wang JJ, Rochtchina E, Smith W, et al. (2004). Impact of bilateral visual impairment on health-related quality of life: the Blue Mountains Eye Study. Invest Ophthalmol Vis Sci.
17 Claiborne N, Massaro E. (2000). Mental quality of life: an indicator of unmet needs in patients with diabetes. Soc Work Health Care.
18 Clarke P, Gray A, Holman R. (2002). Estimating utility values for health states of type 2 diabetic patients using the EQ-5D (UKPDS 62). Med Decis Mak.
19 Clarke PM, Simon J, Cull CA, Holman RR. (2006). Assessing the impact of visual acuity on quality of life in individuals with type 2 diabetes using the short form-36. Diabetes Care.
20 Crewe JM, Morlet N, Morgan WH, et al. (2011). Quality of life of the most severely vision-impaired. Clin Exp Ophthalmol.
21 Covic AM, Iyengar SK, Olson JM, Sehgal AR, et al. (2001). A family-based strategy to identify genes for diabetic nephropathy. Am J Kidney Dis.
22 Dreer LE, Berry J, Rivera P, Snow M, et al. (2009). Efficient assessment of social problem-solving abilities in medical and rehabilitation settings: a Rasch analysis of the Social Problem-Solving Inventory-Revised. J Clin Psychol.
23 Echeverry D, Duran P, Bonds C, Lee M, et al. (2009). Effect of pharmacological treatment of depression on A1C and quality of life in low-income hispanics and African Americans with diabetes: A randomized, double-blind, placebo-controlled trial. Diabetes Care.
24 Espinet LM, Osmick MJ, Ahmed T, Villagra VG. (2005). A cohort study of the impact of a national disease management program on HEDIS diabetes outcomes. Disease Management.
25 Frost NA, Sparrow JM, Durant JS, Donovan JL, et al. (1998). Development of a questionnaire for measurement of vision-related quality of life. Ophthalmic Epidemiol.
26 Gillibrand W. (2000). Users' perception of a mobile diabetic eye-screening service. J Diabetes Nurs.
27 Glasgow RE, Nutting PA, King DK, Nelson CC, et al. (2004). A practical randomized trial to improve diabetes care. J Gen Intern Med.
28 Gulliford MC, Mahabir D. (1999). Relationship of health-related quality of life to symptom severity in diabetes mellitus: A study in Trinidad and Tobago. J Clin Epidemiol.
29 Hahm BJ, Shin YW, Shim EJ, Jeon HJ, et al. (2008). Depression and the vision-related quality of life in patients with retinitis pigmentosa. Br J Ophthalmol.
30 Hawthorne G. (2009). Assessing utility where short measures are required: Development of the short assessment of quality of life-8 (AQoL-8) Instrument. Value Health.
31 Hill-Briggs F, Gary TL, Hill MN, Bone LR, et al. (2002). Health-related quality of life in urban African Americans with type 2 diabetes. J Gen Int Med.
32 Holbrook EA, Caputo JL, Perry TL, Fuller DK, et al. (2009). Physical activity, body composition, and perceived quality of life of adults with visual impairments. J Vis Impair Blind.
33 Holmes J, Mcgill S, Kind P, Bottomley J, et al. (2000). Health-related quality of life in type 2 diabetes. Value Health.
34 Huang F, Yang Q, Chen L, Tang S, et al. (2007). Renal pathological change in patients with type 2 diabetes is not always diabetic nephropathy: a report of 52 cases. Clinical Nephrology.
35 Huang GH, Palta M, Allen C, LeCaire T, et al. (2004). Self-rated health among young people with type 1 diabetes in relation to risk factors in a longitudinal study. Am J Epidemiol.
36 Inoue A. (2000). Visual disability due to diabetic nephropathy and its effect on quality of life in patients on maintenance hemodialysis. Folia Ophthalmol Jpn.
37 Jennings DL, Ragucci KR, Chumney ECG, Wessell AM. (2007). Impact of clinical pharmacist intervention on diabetes related quality-of-life in an ambulatory care clinic. Pharmacy Practice.
38 Ji YH, Park HJ, Oh SY. (1999). Clinical effect of low vision aids. Korean J Ophthalmol.
39 Johnson JA, Maddigan SL. (2004). Performance of the RAND-12 and SF–12 summary scores in type 2 diabetes. Qual Life Res.
40 Jung CS, Bruce B, Newman NJ, Biousse V. (2008). Visual function in anterior ischemic optic neuropathy: effect of Vision Restoration Therapy--a pilot study. J Neurol Sci.
41 Kaholokula JK, Haynes SN, Grandinetti A, Chang HK. (2006). Ethnic differences in the relationship between depressive symptoms and health-related quality of life in people with type 2 diabetes. Ethnicity & Health.
42 Kalter-Leibovici O, Wainstein J, Ziv A, Harman-Bohem I, et al. (2005). Clinical, socioeconomic, and lifestyle parameters associated with erectile dysfunction among diabetic men. Diabetes Care.
43 Kazis LE, Miller DR, Clark JA, Skinner KM, et al. (2004). Improving the response choices on the Veterans SF–36 Health Survey role functioning scales: results from the Veterans Health Study. Journal of Ambulatory Care Management.
44 Kean-Cowdin R, Varma R, Wu J, Hays RD, et al. (2007). Severity of visual field loss and health-related quality of life. Am J Ophthalmol.
45 Keinanen-Kiukaanniemi S, Ohinmaa A, Pajunpaa H, Koivukangas P. (1996). Health related quality of life in diabetic patients measured by the Nottingham Health Profile. Diabet Med.
46 Klein BE, Klein R, Moss SE. (1998). Self-rated health and diabetes of long duration. The Wisconsin Epidemiologic Study of Diabetic Retinopathy. Diabetes Care.
47 Kodjebacheva G, Coleman AL, Ensrud KE, Cauley JA, et al. (2010). Reliability and Validity of Abbreviated Surveys Derived from the National Eye Institute Visual Function Questionnaire: The Study of Osteoporotic Fractures. Am J Ophthalmol.
48 Kohara R, Hirao RA, Kitamura T, Kouhara H. Diabetes Conference: 69th Annual Meeting of the American Diabetes Association.
49 Korkina MV, Elfimova EV. (2003). Diabetes mellitus and depression. Zh Nevrologii Psihiatrii im S S Korsakova.
50 Labiris G, Katsanos A, Fanariotis M, Tsirouki T, et al. (2008). Psychometric properties of the Greek version of the NEI-VFQ 25. BMC Ophtalmol.
51 Leas BF, Berman B, Kash KM, Crawford AG, et al. (2009). Quality measurement in diabetes care. Popul Heath Manage.
52 Lee A. (2000). Knowledge provides the key to successful management of diabetic retinopathy. Ophthalmic Nurs.
53 Lee PP, Whitcup SM, Hays RD, Spritzer K, et al. (1995). The relationship between visual acuity and functioning and well-being among diabetics. Qual Life Res.
54 Lee PP, Spritzer K, Hays RD. (1997). The impact of blurred vision on functioning and well-being. Ophthalmology.
55 Leksell J, Sandberg G, Wikblad K. (2006). Experiences of an educational programme for individuals with blindness caused by diabetes. European Diabetes Nursing.
56 Li Y, Crews JE, Elam-Evans LD, et al. (2011). Visual impairment and health-related quality of life among elderly adults with age-related eye diseases. Qual Life Res.
57 Lloyd CE, Matthews KA, Wing RR, Orchard TJ. (1992). Psychosocial factors and complications of IDDM. The Pittsburgh Epidemiology of Diabetes Complications Study. VIII. Diabetes Care.
58 Lundman B, Asplund K, Norberg A. (1990). Living with diabetes: perceptions of well-being. Res Nurs Health.
59 Ma SL, Shea JA, Galetta SL, Jacobs DA, et al. (2002). Self-reported visual dysfunction in multiple sclerosis: new data from the VFQ–25 and development of an MS-specific vision questionnaire. Am J Ophthalmol.
60 Maahs DM, Gendelman N, Snell-Bergeon JK, McFann K, et al. Diabetes Conference: 69th Annual Meeting of the American Diabetes Association.
61 Maddigan SL, Feeny DH, Johnson JA. (2004). Construct validity of the RAND-12 and Health Utilities Index Mark 2 and 3 in type 2 diabetes. Qual Life Res.
62 Malik RA, W S, A. (1998). Effect of angiotensin-converting-enzyme (ACE) inhibitor trandolapril on human diabetic neuropathy: randomised double-blind controlled trial. Lancet.
63 Martinez-Castelao A, Gorriz JL, Garcia-Lopez F, Lopez-Revuelta K, et al. (2004). Perceived health-related quality of life and comorbidity in diabetic patients starting dialysis (CALVIDIA study). J Nephrol.
64 Mason-Schrock D. (1996). Transsexuals' Narrative Construction of the “True Self”. Soc Psychol Q.
65 McCarty CA, McKay R, Keeffe JE. (2000). Management of diabetic retinopathy by Australian ophthalmologists. Working Group on Evaluation of the NHMRC Retinopathy Guideline Distribution. National Health and Medical Research Council. Clin Exp Ophthalmol.
66 McCarty CA, Wright S, McKay R, Taylor KI, et al. (2001). Changes in management of diabetic retinopathy by Australian ophthalmologists as a result of the NHMRC clinical guidelines. Clin Exp Ophthal.
67 McCarty CA, Taylor KI, McKay R, Keeffe JE, et al. (2001). Diabetic retinopathy: effects of national guidelines on the referral, examination and treatment practices of ophthalmologists and optometrists. Clin Exp Ophthal.
68 McFarland KF, Rhoades DR, Campbell J, Finch WH. (2001). Meaning of illness and health outcomes in type 1 diabetes. Endocr Pract.
69 McGill MJ, Molyneaux LM, O'Dea JA, Yue DK. (1995). Discussing diabetic retinopathy with NIDDM patients: An evaluation of varying the content of information given to patients and its impact on anxiety. Pract Diabetes Int.
70 Mehta Z, Cull C, Stratton I, Yudkin J, et al. (1999). Quality of life in type 2 diabetic patients is affected by complications but not by intensive policies to improve blood glucose or blood pressure control (UKPDS 37). Diabetes Care.
71 Miljanovic B, Dana R, Sullivan DA, Schaumberg DA. (2007). Impact of dry eye syndrome on vision-related quality of life. Am J Ophthalmol.
72 Misajon R, Hawthorne G, Richardson J, Barton J, et al. (2005). Vision and quality of life: The development of a utility measure. Invest Ophthalmol Vis Sci.
73 Miskala PH, Bressler NM, Meinert CL, Scott IU. (2004). Relative contributions of reduced vision and general health to NEI-VFQ scores in patients with neovascular age-related macular degeneration. Evid Based Eye Care.
74 Mitchell J, Bradley C. (2001). Psychometric evaluation of the 12-item Well-being Questionnaire for use with people with macular disease. Qual Life Res.
75 Mitchell J, Bradley C. (2004). Design of an individualised measure of the impact of macular disease on quality of life (the MacDQoL). Qual Life Res.
76 Mitchell J, Wolffsohn JS, Woodcock A, Anderson SJ, et al. (2005). +Psychometric evaluation of the MacDQoL individualised measure of the impact of macular degeneration on quality of life. Health Qual Life Outcomes.
77 Mocan MC, Kadayifcilar S, Eldem B. (2006). Elevated intravitreal interleukin-6 levels in patients with proliferative diabetic retinopathy. Can J Ophthalmol.
78 Mok JY, Laing IA, Farquhar JW. (1984). Young diabetics: memories, current lifestyles and attitudes. Diabet Med.
79 Moon SH, Kim IH, Park SW, Kim I, et al. (2005). Early adjuvant radiotherapy toward long-term survival and better quality of life for craniopharyngiomas--a study in single institute. Childs Nervous System.
80 Mozaffarieh M, Krepler K, Heinzl H, Sacu S, et al. (2004). Visual function, quality of life and patient satisfaction after ophthalmic surgery: a comparative study. Ophthalmologica.
81 Nang EE, Khoo CM, Tai ES, Lim SC, et al. (2009). Is there a clear threshold for fasting plasma glucose that differentiates between those with and without neuropathy and chronic kidney disease?: the Singapore Prospective Study Program. Am J Epidemiol.
82 Nasser J, Habib F, Hasan M, Khalil N. (2009). Prevalence of depression among people with diabetes attending diabetes clinics at primary health settings. Bahrain Med Bull.
83 Nirmalan PK, Tielsch JM, Katz J, Thulasiraj RD, et al. (2005). Relationship between vision impairment and eye disease to vision-specific quality of life and function in rural India: the Aravind Comprehensive Eye Survey. Invest Ophthalmol Vis Sci.
84 O'Connor PJ, Desai JR, Solberg LI, Rush WA, et al. (2003). Variation in diabetes care by age: opportunities for customization of care. BMC Fam Pract.
85 Odin VI, Belikova TV, Pushkova ES. (2002). Diabetes mellitus in the elderly: succinic acid compounds in treating diabetic neuropathies. Adv Gerontol.
86 Okamoto F, Okamoto Y, Hiraoka T, Oshika T. (2008). Vision-related Quality of Life and Visual Function after Retinal Detachment Surgery. Am J Ophthalmol.
87 Okamoto F, Okamoto Y, Hiraoka T, Oshika T. (2009). Effect of Vitrectomy for Epiretinal Membrane on Visual Function and Vision-Related Quality of Life. Am J Ophthalmol.
88 Olsen H, Jeune B, ndersen-Ranberg K. (1996). Centenarians in the county of Funen. Morbidity and functional capacity. Ugeskrift for Laeger.
89 Passamonti M, Pigni M, Colombo L, Sacchi E. (2000). The quality of life of patients with type 2 diabetes mellitus in general practice. Eur J Gen Pract.
90 Raphael BA, Galetta KM, Jacobs DA, Markowitz CE, et al. (2006). Validation and test characteristics of a 10-item neuro-ophthalmic supplement to the NEI-VFQ–25. Am J Ophthalmol.
91 Reeves BC, Langham J, Walker J, Grieve R, et al. (2009). Verteporfin Photodynamic Therapy Cohort Study. Report 2: Clinical Measures of Vision and Health-Related Quality of Life. Ophthalmology.
92 Roh MI, Byeon SH, Kwon OW. (2008). Repeated intravitreal injection of bevacizumab for clinically significant diabetic macular edema. Retina.
93 Salive ME, Guralnik J, Christen W, Glynn RJ, et al. (1992). Functional blindness and visual impairment in older adults from three communities. Ophthalmology.
94 Savoia E, Fantini MP, Pandolfi PP, Dallolio L, et al. (2006). Assessing the construct validity of the Italian version of the EQ-5D: Preliminary results from a cross-sectional study in North Italy. Health Qual Life Outcomes.
95 Schmid KL, Swann PG, Pedersen C, Schmid LM. (2002). The detection of diabetic retinopathy by Australian optometrists. Clin Exp Optometry.
96 Sinclair AJ, Bayer AJ, Girling AJ, Woodhouse KW. (2000). Older adults, diabetes mellitus and visual acuity: a community-based case-control study. Age Ageing.
97 Smith SC. (2007). Nursing interventions for ophthalmic patients with diabetes. Insight.
98 Sousa VD, Zanetti ML, Zausziewski JA, Mendes IAC, et al. (2008). Psychometric properties of the Portuguese version of the Depressive Cognition Scale in Brazilian adults with diabetes mellitus. Journal of Nursing Measurement.
99 Stein JD, Brown MM, Brown GC, Hollands H, et al. (2003). Quality of life with macular degeneration: Perceptions of patients, clinicians and community members. Evid Based Eye Care.
100 Steinberg EP, Tielsch JM, Schein OD, Javitt JC, et al. (1994). The VF–14. An index of functional impairment in patients with cataract. Arch Ophthalmol.
101 Stelmack JA, Moran D, Dean D, Massof RW. (2007). Short- and long-term effects of an intensive inpatient vision rehabilitation program. Arch Phys Med Rehabil.
102 Styles CJ, Park SJ, McGhee CN, Gamble G, et al. (2007). Evaluating the use of a scanning laser-derived oedema index to grade diabetic retinopathy and maculopathy. Clin Exp Ophthalmol.
103 Sugawara T, Kaneko Y. (2004). Report of the second Iwate study trial on complications of diabetes mellitus - Questionnaire survey of patients attending the “DM Eye Seminar”. Folia Ophthalmol Jpn.
104 Sullivan P. (2011). Don't give up on GWAS. Mol Psychiatry.
105 Szlyk JP, Becker JE, Fishman GA, Seiple W. (2001). Psychological profiles of patients with central vision loss. J Vis Impair Blind.
106 Talbot F, Nouwen A, Gingras J, B+®langer A, et al. (1999). Relations of diabetes intrusiveness and personal control to symptoms of depression among adults with diabetes. Health Psychol.
107 Toprak AB, Eser E, Guler C, Baser FE, et al. (2005). Cross-validation of the Turkish version of the 25-item National Eye Institute Visual Functioning Questionnaire (NEI-VFQ 25). Ophthalmic Epidemiol.
108 Tournier M, Moride Y, Ducruet T, Moshyk A, et al. (2008). Depression and mortality in the visually-impaired, community-dwelling, elderly population of Quebec. Acta Opthalmologica.
109 Veen-de Vries NR, Luteijn AJ, Nasiiro RS, Meyboom-de JB. (1999). Health status of the elderly in the Marigot Health District, Dominica. West Indian Med J.
110 Vileikyte L, Leventhal H, Gonzalez JS, Peyrot M, et al. (2005). Diabetic peripheral neuropathy and depressive symptoms: The association revisited. Diabetes Care.
111 Wills CJ, Scott A, Swift PG, Davies MJ, et al. (2003). Retrospective review of care and outcomes in young adults with type 1 diabetes. BMJ.
112 Wright SE, McKay R, Taylor KI, Keeffe JE, et al. (2001). Changes in attitudes and practices of optometrists in their management of diabetic retinopathy after the release of NHMRC guidelines. National Health and Medical Research Council. Clin Exp Ophthal.
113 Yan S, Li Q, Sun YQ. (2005). Multivariate analysis of patients with diabetes mellitus accompanied by depression. Chin J Clin Rehab.
114 Yang Z, Lin W, Moshfeghi DM, Thirumalaichary S, et al. (2003). A novel mutation in the RDS/Peripherin gene causes adult-onset foveomacular dystrophy. Am J Ophthalmol.
115 Zhang CX, Chen YM, Chen WQ. (2008). Association of psychosocial factors with anxiety and depressive symptoms in Chinese patients with type 2 diabetes. Diabetes Res Clin Pract.
116 Zhang X, Gregg EW, Cheng YJ, Thompson TJ, et al. (2008). Diabetes mellitus and visual impairment: national health and nutrition examination survey, 1999-2004. Arch Ophthalmol.
117 Zhou H, Isaman DJ, Messinger S, Brown MB, et al. (2005). A computer simulation model of diabetes progression, quality of life, and cost. Diabetes Care.

## Intervention (n = 99)

1 (1998). Early worsening of diabetic retinopathy in the Diabetes Control and Complications Trial. Arch Ophthalmol.
2 Alva ML, Gray A, Mihaylova B, et al. Diabetologia Conference: 46th Annual Meeting of the European Association for the Study of Diabetes, EASD.
3 Arai M. (2005). Low-vision care for rehabilitation of visually impaired due to diabetic retinopathy. Folia Ophthalmol Jpn.
4 Awdeh RM, Elsing SH, Deramo VA, et al. (2010). Vision-related quality of life in persons with unilateral branch retinal vein occlusion using the 25-item National Eye Institute Visual Function Questionnaire. Br J Ophthalmol.
5 Bamashmus MA, Gunaid AA, Khandekar R. (2009). Regular visits to a diabetes clinic were associated with lower magnitude of visual disability and diabetic retinopathy-a hospital-based historical cohort study in yemen. Diabetes Technol Ther.
6 Bothe N, Hetzer R, Deinlein E. (1992). Patients with late-life vision damage in occupational rehabilitation. Preliminary ophthalmologic treatment, concomitant manifestations and an illustration provided by the growing number of patients with juvenile diabetes. Klin Monatsbl Augenheilkd.
7 Brown MM, Brown GC, Sharma S, et al. (1999). Utility values and diabetic retinopathy. Am J Ophthalmol.
8 Brown MM, Brown GC, Sharma S. (2001). Cost-effective analysis: Diabetic vitrectomy. Evidence-Based Eye Care.
9 Brown MM, Brown GC, Sharma S, et al. (2002). Quality of life with visual acuity loss from diabetic retinopathy and age-related macular degeneration. Arch Ophthalmol.
10 Byeon SH, Kwon OW, Song JH, et al. (2009). Prolongation of activity of single intravitreal bevacizumab by adjuvant topical aqueous depressant (Timolol-Dorzolamide). Graefes Arch Clin Exp Ophthalmol.
11 Cha YJ, Kim SJ. (2007). The therapeutic effects of angiotensin-converting enzyme inhibitors in severe non-proliferative diabetic retinopathy. Korean J Ophthalmol.
12 Chaturvedi N, Porta M, Klein R, et al. (2008). Effect of candesartan on prevention (DIRECT-Prevent 1) and progression (DIRECT-Protect 1) of retinopathy in type 1 diabetes: randomised, placebo-controlled trials. Lancet.
13 Chew EY, Ferris FL, Csaky KG, et al. (2003). The long-term effects of laser photocoagulation treatment in patients with diabetic retinopathy: the early treatment diabetic retinopathy follow-up study. Ophthalmology.
14 Coffey JT, Brandle M, Zhou H, et al. (2002). Valuing health-related quality of life in diabetes. Diabetes Care.
15 Comty CM, Leonard A, Shapiro FL. (1974). Psychosocial problems in dialyzed diabetic patients. Kidney Int Suppl.
16 Coyne KS, Margolis MK, Kennedy-Martin T, et al. (2004). The impact of diabetic retinopathy: perspectives from patient focus groups. Fam Pract.
17 Cusick M, SanGiovanni JP, Chew EY, et al. (2005). Central visual function and the NEI-VFQ-25 near and distance activities subscale scores in people with type 1 and 2 diabetes. Am J Ophthalmol.
18 Dasbach EJ, Klein R, Klein BE, et al. (1994). Self-rated health and mortality in people with diabetes. Am J Public Health.
19 Davidov E, Breitscheidel L, Clouth J, et al. (2009). Diabetic retinopathy and health-related quality of life. Graefes Arch Clin Exp Ophthalmol.
20 Davis MD, Sheetz MJ, Aiello LP, et al. (2009). Effect of ruboxistaurin on the visual acuity decline associated with long-standing diabetic macular edema. Invest Ophthalmol Vis Sci.
21 Diolaiuti S, Senn P, Schmid MK, et al. (2006). Combined pars plana vitrectomy and phacoemulsification with intraocular lens implantation in severe proliferative diabetic retinopathy. Ophthalmic Surg Lasers Imaging.
22 Diskin CJ, Stokes TJ, Dansby LM, et al. (2007). A hypothesis: can erythropoietin administration affect the severity of retinopathy in diabetic patients with renal failure?. Am J Med Sci.
23 Dreer LE, Elliott TR, Berry J, et al. (2008). Cognitive appraisals, distress and disability among persons in low vision rehabilitation. Br J Health Psychol.
24 el Haddad OA, Saad MK. (1998). Prevalence and risk factors for diabetic retinopathy among Omani diabetics. Br J Ophthalmol.
25 Esteban JJ, Martinez MS, Navalon PG, et al. (2008). Visual impairment and quality of life: gender differences in the elderly in Cuenca, Spain. Qual Life Res.
26 Ferguson SC, Blane A, Perros P, et al. (2003). Cognitive ability and brain structure in type 1 diabetes: relation to microangiopathy and preceding severe hypoglycemia. Diabetes.
27 Fernandez GA, Sierra J. (2001). Analysis of eye disease and adaptation of visual aids in low vision patients: review of 1,000 cases. Arch Soc Esp Oftalmol.
28 Finger RP, Kupitz DG, Holz FG, et al. (2011). The impact of the severity of vision loss on vision-related quality of life in india: An evaluation of the IND-VFQ-33. Investigative Ophthalmology and Visual Science.
29 Fu Q, Xu JW. (2006). Effect of intervention via mid-long term follow-up on visual recovery of patients with diabetic retinopathy. Chin J Clin Rehab.
30 Gangnon RE, Davis MD, Hubbard LD, et al. (2008). A severity scale for diabetic macular edema developed from ETDRS data. Invest Ophthalmol Vis Sci.
31 Gheorghiu M. (2000). Oftalmologia.
32 Gheorghiu M. (2001). Oftalmologia.
33 Gheorghiu M. (2001). Oftalmologia.
34 Gilmore ED, Hudson C, Nrusimhadevara RK, et al. (2007). Retinal arteriolar hemodynamic response to an acute hyperglycemic provocation in early and sight-threatening diabetic retinopathy. Microvas Res.
35 Gonzalez Villalpando ME, Gonzalez VC, Arredondo PB, et al. (1997). Moderate-to-severe diabetic retinopathy is more prevalent in Mexico City than in San Antonio, Texas. Diabetes Care.
36 Guleria S, Aggarwal S, Bansal VK, et al. (2005). The first successful simultaneous pancreas-kidney transplant in India. Natl Med J India.
37 Gupta SK, Viswanath K, Thulasiraj RD, et al. (2005). The development of the Indian vision function questionnaire: field testing and psychometric evaluation. Br J Ophthalmol.
38 Hanninen J, Takala J, Keinanen-Kiukaanniemi S. (1998). Quality of life in NIDDM patients assessed with the SF-20 questionnaire. Diabetes Res Clin Pract.
39 Hariprasad SM, Mieler WF, Grassi M, et al. (2008). Vision-related quality of life in patients with diabetic macular oedema. Br J Ophthalmol.
40 Haritoglou C, Gerss J, Sauerland C, et al. (2009). Effect of calcium dobesilate on occurrence of diabetic macular oedema (CALDIRET study): randomised, double-blind, placebo-controlled, multicentre trial. Lancet.
41 Hawkins WR. (2010). Diabetic retinopathy and sodium intake. Arch Ophthalmol.
42 Henricsson M, Nystrom L, Blohme G, et al. (2003). The incidence of retinopathy 10 years after diagnosis in young adult people with diabetes: results from the nationwide population-based Diabetes Incidence Study in Sweden (DISS). Diabetes Care.
43 Hirowatari T. (2005). Evaluation of a new preoperative ophthalmic solution. Can J Ophthalmol.
44 Huang ES, Brown SE, Ewigman BG, et al. (2007). Patient perceptions of quality of life with diabetes-related complications and treatments. Diabetes Care.
45 Jahn CE, Topfner von SK, Richter J, et al. (2004). Improvement of visual acuity in eyes with diabetic macular edema after treatment with pars plana vitrectomy. Ophthalmologica.
46 Joussen AM, Weiss C, Bauer D, et al. (2007). Triamcinolone versus inner-limiting membrane peeling in persistent diabetic macular edema (TIME study): design issues and implications. Graefes Arch Clin Exp Ophthalmol.
47 Karel I, Kalvodova B. (1994). Long-term results of pars plana vitrectomy and silicone oil for complications of diabetic retinopathy. Eur J Ophthalmol.
48 Kawashima D, Ohno T, Kinoshita O, et al. (2011). Prevalence of vitreous hemorrhage following coronary revascularization in patients with diabetic retinopathy. Cir J.
49 Kean-Cowdin R, Varma R, Hays RD, et al. (1907). Longitudinal changes in visual acuity and health-related quality of life: the Los Angeles Latino Eye study. Ophthalmology.
50 Keeffe JE, Lam D, Cheung A, et al. (1998). Impact of vision impairment on functioning. Aust N Z J Ophthalmol.
51 Klein R, Moss SE, Klein BE, et al. (2001). The NEI-VFQ-25 in people with long-term type 1 diabetes mellitus: the Wisconsin Epidemiologic Study of Diabetic Retinopathy. Arch Ophthalmol.
52 Knudtson MD, Klein BE, Klein R, et al. (2005). Age-related eye disease, quality of life, and functional activity. Arch Ophthalmol.
53 Korkeliia MT, Tsupkiridze LR, Kurashvili RB, et al. (2009). Psychopathologic peculiarities in patients with diabetes mellitus and non-proliferative retinopathy. Georgian Med News.
54 Lamoureux EL, Hassell JB, Keeffe JE. (2004). The impact of diabetic retinopathy on participation in daily living. Arch Ophthalmol.
55 Lee SJ, Sicari C, Harper CA, et al. (2000). Examination compliance and screening for diabetic retinopathy: a 2-year follow-up study. Clin Experiment Ophthalmol.
56 Leksell JK, Johansson I, Wibell LB, et al. (2001). Power and self-perceived health in blind diabetic and nondiabetic individuals. J Adv Nurs.
57 Leksell JK, Wikblad KF, Sandberg GE. (2005). Sense of coherence and power among people with blindness caused by diabetes. Diabetes Res Clin Pract.
58 Leksell JK, Sandberg GE, Wikblad KF. (2005). Self-perceived health and self-care among diabetic subjects with defective vision: a comparison between subjects with threat of blindness and blind subjects. J Diabet Complications.
59 Lloyd CE, Orchard TJ. (1999). Physical and psychological well-being in adults with Type 1 diabetes. Diabetes Res Clin Pract.
60 Luckie R, Leese G, McAlpine R, et al. (2007). Fear of visual loss in patients with diabetes: Results of the Prevalence of Diabetic Eye Disease in Tayside, Scotland (P-DETS) study. Diabet Med.
61 Maia OO, Takahashi WY, Bonanomi MT, et al. (2007). Visual stability in diabetic retinopathy treated by panretinal laser photocoagulation. Arq Bras Endocrinol Metabol.
62 Maia OO, Takahashi WY, Sampaio MW, et al. (2007). Contrast sensitivity in diabetic retinopathy treated with argon laser panphotocoagulation. Arq Bras Oftalmol.
63 Mason JO, Yunker JJ, Vail R, et al. (2008). Intravitreal bevacizumab (Avastin) prevention of panretinal photocoagulation-induced complications in patients with severe proliferative diabetic retinopathy. Retina.
64 Mata Cases M, Roset Gamisans M, Badia Llach X, et al. (2003). Effect of type-2 diabetes mellitus on the quality of life of patients treated at primary care consultations in Spain. Aten Prim.
65 Mazhar K, Varma R, Choudhury F, et al. (2011). Severity of Diabetic Retinopathy and Health-Related Quality of Life The Los Angeles Latino Eye Study. Ophthalmology.
66 Murthy GV, Gupta SK, Thulasiraj RD, et al. (2005). The development of the Indian vision function questionnaire: questionnaire content. Br J Ophthalmol.
67 Nawrocki J, Chrzanowski W, Koch D, et al. (1997). Vitreoretinal surgery in diabetic patients on hemodialysis. Eur J Ophthalmol.
68 Nemeth B, Hudomel J, Farkas A. (1975). Effect of calcium dobesilate (Doxium) on circulatory disorders of the retina with special emphasis on diabetic retinopathy. Ophthalmologica.
69 Ramalho LH, Avila MP, Moraes Junior HV, et al. (2009). Subclinical diabetic macular edema and mild non-proliferative diabetic retinopathy: data correlation with the retinal thickness analyzer (RTA). Arq Bras Oftalmol.
70 Ramezani AR, Ahmadieh H, Ghaseminejad AK, et al. (2005). Effect of tranexamic acid on early postvitrectomy diabetic haemorrhage; a randomised clinical trial. Br J Ophthalmol.
71 Real FJ, Brown GC, Brown HC, et al. (2008). The effect of comorbidities upon ocular and systemic health-related quality of life. Br J Ophthalmol.
72 Robertson N, Burden ML, Burden AC. (2006). Psychological morbidity and problems of daily living in people with visual loss and diabetes: do they differ from people without diabetes?. Diabet Med.
73 Rohrschneider K, Bruder I, Aust R, et al. (1997). Use of a new optoelectronic vision aid for highly visually handicapped patients. Klin Monatsbl Augenheilkd.
74 Rossi GC, Milano G, Tinelli C. (2003). The Italian version of the 25-item National Eye Institute Visual Function Questionnaire: translation, validity, and reliability. J Glaucoma.
75 Roy A, Roy M. (2001). Depressive symptoms in African-American type 1 diabetics. Depress Anxiety.
76 Sakamaki H, Ikeda S, Ikegami N, et al. (2006). Measurement of HRQL using EQ-5D in patients with type 2 diabetes mellitus in Japan. Value Health.
77 Sasaki S, Tsuru NE, Inoguchi T, et al. (2005). Incidence of latent depression associated with diabetic retinopathy and utility of SRQ-D in diagnosis. Folia Ophthalmol Jpn.
78 Scalinci SZ, Simoni P, Scorolli L, et al. (1997). Visual rehabilitation in advanced diabetic retinopathy. Ann Ottalmol Clin Ocul.
79 Schweitzer KD, Eneh AA, Hurst J, et al. (2011). Visual function analysis in acute posterior vitreous detachment. Can J Ophthalmol.
80 Searle A, Wetherell MA, Campbell R, et al. (2008). Do patients' beliefs about type 2 diabetes differ in accordance with complications: an investigation into diabetic foot ulceration and retinopathy. Int J Behav Med.
81 Sharma S, Brown GC, Brown MM, et al. (2000). The cost-effectiveness of grid laser photocoagulation for the treatment of diabetic macular edema: results of a patient-based cost-utility analysis. Curr Opin Ophthalmol.
82 Sharma S, Hollands H, Brown GC, et al. (2001). The cost-effectiveness of early vitrectomy for the treatment of vitreous hemorrhage in diabetic retinopathy. Curr Opin Ophthalmol.
83 Sharma S, Oliver-Fernandez A, Bakal J, et al. (2003). Utilities associated with diabetic retinopathy: results from a Canadian sample. Br J Ophthalmol.
84 Shimura M, Yasuda K, Shiono T. (2006). Posterior sub-Tenon's capsule injection of triamcinolone acetonide prevents panretinal photocoagulation-induced visual dysfunction in patients with severe diabetic retinopathy and good vision. Ophthalmology.
85 Sjolie AK, Klein R, Porta M, et al. (2008). Effect of candesartan on progression and regression of retinopathy in type 2 diabetes (DIRECT-Protect 2): a randomised placebo-controlled trial. Lancet.
86 Smith DH, Johnson ES, Russell A, et al. (2008). Lower visual acuity predicts worse utility values among patients with type 2 diabetes. Qual Life Res.
87 Smith TS, Szetu J, Bourne RR. (2007). The prevalence and severity of diabetic retinopathy, associated risk factors and vision loss in patients registered with type 2 diabetes in Luganville, Vanuatu. Br J Ophthalmol.
88 Sugitani A, Hotta K, Suzuki T, et al. (2003). Daily activities of patients with low vision associated with diabetic ocular complications. Folia Ophthalmol Jpn.
89 Takeda M. (2003). Validity of low-vision aids for patients with vision impairment due to diabetic retinopathy. Folia Ophthalmol Jpn.
90 Trento M, Tomelini M, Lattanzio R, et al. (2006). Perception of, and anxiety levels induced by, laser treatment in patients with sight-threatening diabetic retinopathy. A multicentre study. Diabet Med.
91 van Nispen RM, de Boer MR, Hoeijmakers JG, et al. (2009). Co-morbidity and visual acuity are risk factors for health-related quality of life decline: five-month follow-up EQ-5D data of visually impaired older patients. Health Qual Life Ooutcomes.
92 Verma SK, Luo N, Subramaniam M, et al. (2010). Impact of depression on health related quality of life in patients with diabetes. Ann Acad Med Singap.
93 Williams GP, Pathak-Ray V, Austin MW, et al. (2007). Quality of life and visual rehabilitation: an observational study of low vision in three general practices in West Glamorgan. Eye.
94 Wu WC, Hsu KH, Chen TL, et al. (2006). Interventions for relieving pain associated with panretinal photocoagulation: a prospective randomized trial. Eye.
95 Yalcin BM, Karahan TF, Ozcelik M, et al. (2008). The effects of an emotional intelligence program on the quality of life and well-being of patients with type 2 diabetes mellitus. Diabetes Educ.
96 Yamada Y, Hirasawa Y, Ohishi M, et al. (2003). Rehabilitation of the once-sighted blind report 8 - employment of visually impaired and blind. Folia Ophthalmol Jpn.
97 Yamada Y, Hirasawa Y, Takasawa T, et al. (2004). Vision rehabilitation for the once-sighted blind report 9 - frequency and characteristics of sleep disturbance and depression among visually impaired patients. Folia Ophthalmol Jpn.
98 Yamada Y, Hirasawa Y, Ohishi M, et al. (2004). Improving independence of the visually impaired - effectiveness of a vision clinic and personal computer class. Folia Ophthalmol Jpn.
99 Yeoh J, Williams C, Allen P, et al. (2008). Avastin as an adjunct to vitrectomy in the management of severe proliferative diabetic retinopathy: a prospective case series. Clin Experiment Ophthalmol.

## Outcome (n = 185)

1 (1982). Effect of 6 months of strict metabolic control on eye and kidney function in insulin-dependent diabetics with background retinopathy. Steno study group. Lancet.
2 (1995). The effect of intensive diabetes therapy on the development and progression of neuropathy. The Diabetes Control and Complications Trial Research Group. Ann Intern Med.
3 (1998). Even modest improvements in blood sugar control can substantially improve quality of life for people with diabetes. AHRQ Research Activities.
4 (2000). Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy. The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group. New Engl J Med.
5 Abdoli S, Ashktorab T, Ahmadi F, Parvizi S, et al. (2008). The empowerment process in people with diabetes: an Iranian perspective. Int Nurs Rev.
6 Ahmadian L, Moradi, Lopez JA, Mayers M, et al. Diabetes Conference: 69th Annual Meeting of the American Diabetes Association.
7 Ahola AJ, Saraheimo M, Forsblom C, Hietala K, et al. (2010). Health-related quality of life in patients with type 1diabetes-association with diabetic complications (the FinnDiane Study). Nephrol Dial Transplant.
8 Airaksinen KE, Salmela PI, Miettinen RU, Ikaheimo MJ, et al. (1990). Effect of coronary artery bypass surgery on autonomic nervous function and retinopathy in diabetic patients. Diabetes Res.
9 Akatsuka R. (1987). Kango Gijutsu.
10 Al-Ansari SA, Tennant MTS, Greve MDJ, Hinz BJ, et al. (2009). Short report: suboptimal diabetes care in high-risk diabetic patients attending a specialist retina clinic. Diabet Med.
11 Al-Ghamdi AA. (2004). A high prevalence of depression among diabetic patients at a teaching hospital in Western Saudi Arabia. Neurosciences.
12 Al-Tuwijri AA, Al-Doghether MH, Akturk Z, Al-Megbil TI. (2007). Quality of life of people with diabetes attending primary care health centres in Riyadh: bad control -- good quality?. Quality in Primary Care.
13 Almond C, Hayward E, Freemantle N, Brereton NJ. (2011). The use of a mixed-treatment comparison to assess the costeffectiveness of ozurdex (dexamethasone intravitreal implant in applicator) compared with bevacizumab intravitreal injections for patients with macular oedema following branch retinal vein occlusion.
14 Amsberg S, Anderbro T, Wredling R, Lisspers J, et al. (2009). A cognitive behavior therapy-based intervention among poorly controlled adult type 1 diabetes patients-A randomized controlled trial. Patient Educ Couns.
15 Anaforoglu I, Atasoy V, Algn E, Kutanis R. Endocrine Abstracts Conference: 12th European Congress of Endocrinology.
16 Ando N, Iwaki H. (2000). An attempt to better control diabetic retinopathy. Folia Ophthal Jap.
17 Araki A, Izumo Y, Inoue J, Takahashi R, et al. (1995). Factors associated with increased diabetes burden in elderly diabetic patients. Nippon Ronen Igakkai Zasshi.
18 Arevalo JF, Sanchez JG, Fromow-Guerra J, Wu L, et al. (2009). Comparison of two doses of primary intravitreal bevacizumab (Avastin) for diffuse diabetic macular edema: results from the Pan-American Collaborative Retina Study Group (PACORES) at 12-month follow-up. Graefes Archive for Clin Exp Ophthalmol.
19 Bagust A, Beale S. (2005). Modelling EuroQol health-related utility values for diabetic complications from CODE-2 data. Health Econ.
20 Bailey CC, Sparrow JM. (2001). Visual symptomatology in patients with sight-threatening diabetic retinopathy. Diabet Med.
21 Baker RS, Bazargan M, Calderon JL, Hays RD. (2006). Psychometric Performance of the National Eye Institute Visual Function Questionnaire in Latinos and Non-Latinos. Ophthalmology.
22 Balarin SV, Temporini ER, De Carvalho Moreira FD, Kara-Jose N. (2005). Treatment of diabetic retinopathy: Patients' perceptions in Rio Claro (Sao Paulo State) - Brazil. Arq Bras Oftalmol.
23 Bek T, Moller F, Klausen B. (2000). Short item visual prognosis after retinal laser photocoagulation for diabetic maculopathy. Acta Ophthalmol Scand.
24 Bernbaum M, Albert SG, Brusca SR, Drimmer A, et al. (1989). A model clinical program for patients with diabetes and vision impairment. Diabetes Educ.
25 Bickerdike C, Mellor CM. (2001). ROP rivisited: a survey of adults with residual vision… retinopathy of prematurity. J Vis Impair Blind.
26 Brands AMA, Van Den Berg E, Manschot SM, Biessels GJ, et al. (2007). A detailed profile of cognitive dysfunction and its relation to psychological distress in patients with type 2 diabetes mellitus. J Int Neuropsychol Soc.
27 Brennig C, Schollbauer V, Walter E, Gallagher M, et al. (2011). Economic evaluation of ranibizumab in the treatment of visual impairment due to diabetic macular edema in Austria.
28 Brose LS, Bradley C. (2009). Psychometric development of the retinopathy treatment satisfaction questionnaire (RetTSQ). Psychol Health Med.
29 Brose LS, Bradley C. (2010). Psychometric development of the individualized Retinopathy-Dependent Quality of Life questionnaire (RetDQoL). Value Health.
30 Brown DM, Campochiaro PA, Bhisitkul RB, et al. (2011). Sustained benefits from ranibizumab for macular edema following branch retinal vein occlusion: 12-month outcomes of a phase III study. Ophthalmology.
31 Brown GC, Brown MM, Sharma S, Brown H, et al. (2000). Quality of life associated with diabetes mellitus in an adult population. J Diabetes Complications.
32 Brown MM, Brown GC, Sharma S, Busbee B, et al. (2003). Quality of life associated with visual loss. Evid Based Eye Care.
33 Brown SES, Meltzer DO, Chin MH, Huang ES. (2008). Perceptions of quality-of-life effects of treatments for diabetes mellitus in vulnerable and nonvulnerable older patients. J Am Geriatr Soc.
34 Bursell SE, Clermont AC, Aiello LP, Schlossman DK, et al. (1999). High-dose vitamin E supplementation normalizes retinal blood flow and creatinine clearance in patients with type 1 diabetes. Diabetes Care.
35 Burton AJ, Reynolds A, O'Neill D. (2000). Sildenafil (Viagra) a cause of proliferative diabetic retinopathy?. Eye.
36 Chang K. (2010). Comorbidities, quality of life and patients' willingness to pay for a cure for type 2 diabetes in Taiwan. Public Health.
37 Chang PY, Yang CM, Yang CH, Chen MS, et al. (2009). Pars plana vitrectomy for diabetic fibrovascular proliferation with and without internal limiting membrane peeling. Eye.
38 Chatziralli IP, Kanonidou E, Papazisis L. (2011). Frequency of fundus pathology related to patients' dissatisfaction after phacoemulsification cataract surgery. Bulletin de la Societe Belge d Ophtalmologie.
39 Chen P, He XG. (2005). Visual function of patients with diabetic retinopathy and the intervention of dan-shen root: Quantified evaluation of sight and visual acuity. Chin J Clin Rehab.
40 Chuang LM, Tsai ST, Huang BY, Tai TY. (2002). The status of diabetes control in Asia - A cross-sectional survey of 24 317 patients with diabetes mellitus in 1998. Diabet Med.
41 Chui L. (2005). Fifteen Year Followup of the Ocular and Medical Status of Early Treatment Diabetic Retinopathy Study (ETDRS) Patients Enrolled at the Joslin Diabetes Center. IOVS.
42 Cruickshanks KJ, Moss SE, Klein R, Klein BE. (1995). Physical activity and the risk of progression of retinopathy or the development of proliferative retinopathy. Ophthalmology.
43 Cugati S, Kifley A, Mitchell P, Wang JJ. (2006). Temporal trends in the age-specific prevalence of diabetes and diabetic retinopathy in older persons: Population-based survey findings. Diabetes Res Clin Pract.
44 Cumba RJ, Al-Attar L. Clinical and Translational Science Conference: 2010 Clinical and Translational Research and Education Meeting: ACRT.
45 De Mendonca RHF, Zihlmann KF, Freire ML, De Salles Oliveira RC, et al. (2008). Quality of life in patients with Proliferative Diabetic Retinopathy. Rev Bras Oftalmol.
46 De Visser CL, Bilo HJG, Groenier KH, De Visser W, et al. (2002). The influence of cardiovascular disease on quality of life in type 2 diabetics. Qual Life Res.
47 Didjurgeit U, Kruse J, Schmitz N, Stuckenschneider P, et al. (2002). A time-limited, problem-orientated psychotherapeutic intervention in Type 1 diabetic patients with complications: a randomized controlled trial. Diabet Med.
48 Donnio-Cordoba A, Richer R, Spinelli F, Merle H. (2001). Diabetic retinopathy in Martinique: results of a cross-sectional survey based on 771 patients. Journal Francais d Opthalmologie.
49 Dreer LE, Elliott TR, Fletcher DC, Swanson M. (2005). Social problem-solving abilities and psychological adjustment of persons in low vision rehabilitation. Rehabil Psychol.
50 El-Asrar AM, Al-Rubeaan KA, Al-Amro SA, Kangave D, et al. (1998). Risk factors for diabetic retinopathy among Saudi diabetics. Int Ophthalmol.
51 Escarce JJ, Kapur K, Solomon MD, Mangione CM, et al. (2003). Practice characteristics and HMO enrollee satisfaction with specialty care: an analysis of patients with glaucoma and diabetic retinopathy. Health Serv Res.
52 Fevzi A, Aysegul Y. (2008). Psychometric performance of the National Eye Institute 25-Item Visual Function Questionnaire: In Turkish diabetic retinopathy patients. The Patient: Patient-Centered Outcomes Research.
53 Fonda SJ, Bursell SE, Lewis DG, Garren J, et al. (2007). The relationship of a diabetes telehealth eye care program to standard eye care and change in diabetes health outcomes. Telemed J E Health.
54 Fraenkel G, Comaish I, Lawless MA, Kelly MR, et al. (2004). Development of a Questionnaire to Assess Subjective Vision Score in Myopes Seeking Refractive Surgery. J Refractive Surg.
55 Fukino O, Shinzato R, Ishizu H, Tamai H. (1985). Psychological features of diabetics with severe complications (retinopathy). J Jpn Diabetes Soc.
56 Gabrielian A, Hariprasad SM, Jager RD, Green JL, et al. (2010). The utility of visual function questionnaire in the assessment of the impact of diabetic retinopathy on vision-related quality of life. Eye.
57 Gardner TW, Miller ML, Cunningham D, Blankenship GW. (1995). The retinal depression sign in diabetic retinopathy. Graefes Archive for Clin Exp Ophthalmol.
58 Gendelman N, Snell-Bergeon JK, McFann K, Kinney G, et al. (2009). Prevalence and correlates of depression in individuals with and without type 1 diabetes. Diabetes Care.
59 Goddijn P, Bilo H, Meadows K, Groenier K, et al. (1996). The validity and reliability of the Diabetes Health Profile (DHP) in NIDDM patients referred for insulin therapy. Qual Life Res.
60 Gottsater A, Kangro M, Sundkvist G. (2004). Early parasympathetic neuropathy associated with elevated fasting plasma C-peptide concentrations and late parasympathetic neuropathy with hyperglycaemia and other microvascular complications. Diabet Med.
61 Graham JE, Stoebner-May DG, Ostir GV, Al Snih S, et al. (2007). Health related quality of life in older Mexican Americans with diabetes: A cross-sectional study. Health Qual Life Outcomes.
62 Haber LD. (1971). Disabling effects of chronic disease and impairment. J Chronic Dis.
63 Hahl J, Hamalainen H, Sintonen H, Simell T, et al. (2002). Health-related quality of life in type 1 diabetes without or with symptoms of long-term complications. Qual Life Res.
64 Hahl J, Hamalainen H, Simell T, Simell O. (2006). The effects of type 1 diabetes and its long-term complications on physical and mental health status. Pharmacoeconomics.
65 Haig J, Lawrence D, Barbeau M, Blouin J, et al. (2011). Economic evaluation of ranibizumab for the treatment of diabetic macular edema in Canada.
66 Hanninen J, Keinanen-Kiukaanniemi S, Takala J. (1998). Population-based audit of non-insulin-dependent diabetic patients aged under 65 years in primary health care. Scand J Prim Health Care.
67 Harris EL, Sherman SH, Georgopoulos A. (1999). Black-white differences in risk of developing retinopathy among individuals with type 2 diabetes. Diabetes Care.
68 Hart HE, Bilo HJG, Redekop WK, Stolk RP, et al. (2003). Quality of life of patients with type I diabetes mellitus. Qual Life Res.
69 Hart HE, Redekop WK, Bilo HJG, Meyboom-de JB, et al. (2007). Health related quality of life in patients with type I diabetes mellitus: Generic & disease-specific measurement. Indian J Med Res.
70 Harzallah F, Alberti H, Kanoun F, Elhouch F, et al. (2004). Quality of care of patients with type 2 diabetes in a Tunisian university hospital. Diabetes Metab.
71 Hayashi K, Igarashi C, Hirata A, Hayashi H. (2009). Changes in diabetic macular oedema after phacoemulsification surgery. Eye.
72 Hayward E, Almond C, Trueman D, Yeh WS, et al. (2011). The cost-effectiveness of ozurdex (dexamethasone intravitreal implant in applicator) compared with observation for the treatment of macular oedema following central and branch retinal vein occlusion.
73 Heggie J. (2002). Effectiveness of diabetes eye health education during retinal screening. Diabetes Prim Care.
74 Heller S, Evans AT, Kazlauskaite R. (2003). Training in flexible intensive insulin management improved glycaemic control and quality of life in type 1 diabetes. Evid Based Med.
75 Henricsson M, Heijl A. (1994). The effect of panretinal laser photocoagulation on visual acuity, visual fields and on subjective visual impairment in preproliferative and early proliferative diabetic retinopathy. Acta Ophthalmol.
76 Herpertz S, Johann B, Lichtblau K, Stadtb+ñumer M, et al. (2000). Psychosocial stress and use of psychosocial support in patients with diabetes mellitus. Med Klin.
77 Hollands H, Lam M, Pater J, Sharma S, et al. (2002). Reliability of the time trade-off technique of utility assessment in patients with retinal disease. Evid Based Eye Care.
78 Hoogma RPLM, Spijker AJM, van Doorn-Scheele M, van Doorn TT, et al. (2004). Quality of life and metabolic control in patients with diabetes mellitus type I treated by continuous subcutaneous insulin infusion or multiple daily insulin injections. Neth J Med.
79 Huang IC, Liu JH, Wu AW, Wu MY, et al. (2008). Evaluating the reliability, validity and minimally important difference of the Taiwanese version of the diabetes quality of life (DQOL) measurement. Health Qual Life Outcomes.
80 Huang IC, Hwang CC, Wu MY, Lin W, et al. (2008). Diabetes-specific or generic measures for health-related quality of life? Evidence from psychometric validation of the D-39 and SF–36. Value Health.
81 Inoda S, Shimizu Y, Makino S. (1996). Vitrectomy for proliferative diabetic retinopathy. Folia Ophthal Jap.
82 Ishii H. (1996). Psychosocial problems and their management in patients with diabetic retinopathy. Folia Ophthal Jap.
83 Iyigun E, Bayer A, Tastan S, Demiralp M, et al. (2010). Validity and reliability study for the NEI-VFO-39 scale in chronic ophthalmic diseases - Turkish version. Acta Ophthalmol.
84 Jacko JA, Barnard L, Yi JS, Edwards PJ, et al. (2005). Empirical validation of the WINDOWS accessibility settings and multimodal feedback for a menu selection task for users with diabetic retinopathy. Behav Info Tech.
85 Jacobson AM, Rand LI, Hauser ST. (1985). Psychologic stress and glycemic control: a comparison of patients with and without proliferative diabetic retinopathy. Psychosom Med.
86 Jones HL, Walker EA, Schechter CB, Blanco E. (2010). Vision is precious: a successful behavioral intervention to increase the rate of screening for diabetic retinopathy for inner-city adults. Diabetes Educ.
87 Joussen AM. (2005). Triamcinolone versus Inner-Limiting Membrane Peeling for Diffuse Macular Edema (TIME Study): Design Issues and Implications. IOVS.
88 Kamel HK, Shareeff M, Guro-Razuman S, Mir T. (1999). Vision impairment and impact on functional and psychological assessments in elderly patients. J Invest Med.
89 Karel I, Kalvodova B, Kondrova J, Bedrich P, et al. (1989). Ceskoslovenska Oftalmologie.
90 Karlson B, Agardh CD. (1997). Burden of illness, metabolic control, and complications in relation to depressive symptoms in IDDM patients. Diabet Med.
91 Kawashima D, Ohno T, Kinoshita O, et al. (2011). Prevalence of vitreous hemorrhage following coronary revascularization in patients with diabetic retinopathy. Circulation Journal.
92 Kempen JH, O'Colmain BJ, Leske MC, Haffner SM, et al. (2004). The prevalence of diabetic retinopathy among adults in the United States. Arch Ophthalmol.
93 Khatib FA, Jarrah NS, Shegem NS, Bateiha AM, et al. (2006). Sexual dysfunction among Jordanian men with diabetes. Saudi Medical Journal.
94 Kinder LS, Katon WJ, Ludman E, Russo J, et al. (2006). Improving depression care in patients with diabetes and multiple complications. J Gen Intern Med.
95 Klein R, Klein BE, Moss SE, Cruickshanks KJ. (1998). The Wisconsin Epidemiologic Study of Diabetic Retinopathy: XVII. The 14-year incidence and progression of diabetic retinopathy and associated risk factors in type 1 diabetes. Ophthalmology.
96 Klein R, Moss SE, Klein BEK, Gutierrez P, et al. (2002). The NEI-VFQ–25 in people with long-term type 1 diabetes mellitus: The Wisconsin epidemiology study of diabetic retinopathy. Evid Based Eye Care.
97 Knudsen MS, Thomas S, Gallagher M, Mitchell P. (2011). Assessment of utility loss from diabetic macular edema based on restore trial. Value in Health.
98 Koerner F, Koerner U, Eichenseher N. (1977). Diabetic retinopathy study. Data acquisition and its reliability. Albrecht Von Graefes Archiv fur Klinische und Experimentelle Ophthalmologie.
99 Komatsu M, Kifune M, Shimizu Y, Nawashima M. (1996). Social support for patients with visual disorders - The role of social workers. Folia Ophthalmol Jpn.
100 Koopmanschap M. (2002). Coping with Type II diabetes: The patient's perspective. Diabetologia.
101 Kunimatsu S, Kato S, Sumi I, Kitazawa M, et al. (2007). Evaluation of quality of life characteristics and grade of legal visual impairment. Nippon Ganka Gakkai Zasshi.
102 Kwiatkowski A, Michalak G, Czerwinski J, Wszola M, et al. (2005). Quality of life after simultaneous pancreas-kidney transplantation. Transplant Proc.
103 Lamoureux EL, Hassell JB, Keeffe JE. (2004). The determinants of participation in activities of daily living in people with impaired vision. Am J Ophthalmol.
104 Lamoureux EL, Pallant JF, Pesudovs K, Hassell JB, et al. (2006). The impact of vision impairment questionnaire: An evaluation of its measurement properties using Rasch analysis. Invest Ophthalmol Vis Sci.
105 Lamoureux EL, Tee HW, Pesudovs K, Pallant JF, et al. (2009). Can clinicians use the PHQ-9 to assess depression in people with vision loss?. Optom Vis Sci.
106 Lamoureux EL, Pesudovs K, Thumboo J, Saw SM, et al. (2009). An evaluation of the reliability and validity of the visual functioning questionnaire (VF-11) using rasch analysis in an Asian population. Invest Ophthalmol Vis Sci.
107 Langelaan M, de Boer MR, van Nispen RM, Wouters B, et al. (2007). Impact of visual impairment on quality of life: a comparison with quality of life in the general population and with other chronic conditions. Ophthalmic Epidemiol.
108 Larsson D, Lager I, Nilsson PM. (1999). Socio-economic characteristics and quality of life in diabetes mellitus--relation to metabolic control. Scand J Public Health.
109 Lee HJ, Chapa D, Kao CW, Jones D, et al. (2009). Depression, quality of life, and glycemic control in individuals with type 2 diabetes. J Am Acad Nurse Pract.
110 Lin JC, Chie WC. (2010). Psychometric validation of the Taiwan Chinese version of the 25-Item National Eye Institute Visual Functioning Questionnaire. J Eval Clin Pract.
111 Linder M, Chang TS, Scott IU, Hay D, et al. (1999). Validity of the visual function index (VF–14) in patients with retinal disease. Arch Ophthalmol.
112 Lloyd A, Sawyer W, Hopkinson P. (2001). Impact of long-term complications on quality of life in patients with type 2 diabetes not using insulin. Value Health.
113 Lloyd CE, Pambianco G, Orchard TJ. Diabetes Conference: 69th Annual Meeting of the American Diabetes Association.
114 Lloyd CE, Pambianco G, Orchard TJ. (2010). Does diabetes-related distress explain the presence of depressive symptoms and/or poor self-care in individuals with Type 1 diabetes?. Diabet Med.
115 Lu YW, Ding HF, Wu XL, Kong N, et al. (2005). Correlative analysis between social support and quality of life in patients with diabetic retinopathy. Chin J Clin Rehab.
116 Lustman PJ, Griffith LS, Clouse RE. (1988). Depression in adults with diabetes. Results of 5-yr follow-up study. Diabetes Care.
117 Maddigan SL, Majumdar SR, Toth EL, Feeny DH, et al. (2003). Health-related quality of life deficits associated with varying degrees of disease severity in type 2 diabetes. Health Qual Life Outcomes.
118 Mangione CM, Berry S, Spritzer K, Janz NK, et al. (1998). Identifying the content area for the 51-item National Eye Institute Visual Function Questionnaire: results from focus groups with visually impaired persons. Arch Ophthalmol.
119 Mangione CM, Lee PP, Pitts J, Gutierrez P, et al. (1998). Psychometric properties of the National Eye Institute Visual Function Questionnaire (NEI-VFQ). NEI-VFQ Field Test Investigators. Arch Ophthalmol.
120 Mangione CM, Lee PP, Gutierrez PR, Spritzer K, et al. (2001). Development of the 25-item National Eye Institute Visual Function Questionnaire. Arch Ophthalmol.
121 Mangione CM, Lee PP, Gutierrez PR, Spritzer K, et al. (2002). Development of the 25-item National Eye Institute visual function questionnaire. Evid Based Eye Care.
122 Maturi RK, Merrill PT, Lomeo MD, az-Rohena R, et al. (1999). Perfluoro-N-octane (PFO) in the repair of complicated retinal detachments due to severe proliferative diabetic retinopathy. Ophthalmic Surg Lasers.
123 McClean MT, Andrews WJ, McElnay JC. (2005). Characteristics associated with neuropathy and/or retinopathy in a hospital outpatient diabetic clinic. Pharm World Sci.
124 McCloud C, Harrington A, King L. (2012). Understanding people's experience of vitreoretinal day surgery: A Gadamerian-guided study. J Adv Nurs.
125 McNeely MJ, Boyko EJ. (2005). Diabetes-related comorbidities in Asian Americans: results of a national health survey. J Diabetes Complications.
126 Miettinen H, Haffner SM, Lehto S, Ronnemaa T, et al. (1996). Retinopathy predicts coronary heart disease events in NIDDM patients. Diabetes Care.
127 Moore JE, Giesen JM, Weber JM, Crews JE. (2001). Functional outcomes reported by consumers of the Independent Living Program for Older Individuals Who Are Blind. J Vis Impair Blind.
128 Moore LW, Miller M. (2003). Older men's experiences of living with severe visual impairment. J Adv Nurs.
129 Morgan CL, McEwan P, Morrissey M, Peters JR, et al. (2006). Characterization and comparison of health-related utility in people with diabetes with various single and multiple vascular complications. Diabet Med.
130 Moss SE, Klein R, Sjolie AK, et al. (2011). Angiotensin receptor blockade not related to history of dry eye symptoms and treatment in The Diabetic Retinopathy Candesartan Trials (DIRECT). Acta Opthalmologica.
131 Nakatani S, Ishida M, Yanashima K. (1997). Problems in low vision patients with diabetic retinopathy. Folia Ophthal Jap.
132 Navuluri RB. (2000). Diabetic retinopathy screening among Hispanics in Lea County, New Mexico. J Health Care Poor Underserved.
133 Neves C, Carvalheiro M, Ferreira P. (2002). Quality of life in people with diabetes mellitus. Arq Med.
134 Nguyen TT, Wong TY, Islam FM, Hubbard L, et al. (2008). Is depression associated with microvascular disease in patients with type 2 diabetes?. Depress Anxiety.
135 Oehler-Giarratana J, Fitzgerald RG. (1980). Group therapy with blind diabetics. Arch Gen Psychiatry.
136 Oehler JW. (1984). An exploratory study of psychological reactions to visual loss and blindness in patients with diabetic retinopathy.
137 Pahor D. (1998). Visual field loss after argon laser panretinal photocoagulation in diabetic retinopathy: full- versus mild-scatter coagulation. Int Ophthalmol.
138 Papadopoulos AA, Kontodimopoulos N, Frydas A, Ikonomakis E, et al. (2007). Predictors of health-related quality of life in type II diabetic patients in Greece. BMC Public Health.
139 Phillips CJ, Harper GAD, Waheed N, Owens DR, et al. (1997). Screening for diabetic retinopathy: The costs to patients - A pilot study. Pract Diabetes Int.
140 Quandt SA, Graham CN, Bell RA, Snively BM, et al. (2007). Ethnic disparities in health-related quality of life among older rural adults with diabetes. Ethn Dis.
141 Ragnarson TG, Apelqvist J. (2000). Health-related quality of life in patients with diabetes mellitus and foot ulcers. J Diabetes Complications.
142 Roy MS, Klein R, O'Colmain BJ, Klein BE, et al. (2004). The prevalence of diabetic retinopathy among adult type 1 diabetic persons in the United States. Arch Ophthalmol.
143 Roy MS, Roy A, Affouf M. (2007). Depression is a risk factor for poor glycemic control and retinopathy in African-Americans with type 1 diabetes. Psychosom Med.
144 Roy MS, Peng B, Roy A. (2007). Risk factors for coronary disease and stroke in previously hospitalized African-Americans with Type 1 diabetes: a 6-year follow-up. Diabet Med.
145 Rubin RJ, Dietrich KA, Hawk AD. (1998). Clinical and economic impact of implementing a comprehensive diabetes management program in managed care. J Clin Endocrinol Met.
146 Saatcioglu O, Celikel FC, Kutluturk F, Elbozan Cumurcu B, et al. (2008). Disability and quality of life in patients with type 2 diabetes mellitus. Anatolian J Clin Invest.
147 Saglam ZA, Saler T, Ataoglu E, Temiz LU, et al. (2010). The frequency of depression in turkish patients with diabetes and diabetic complications. Endocrinologist.
148 Sakthong P, Charoenvisuthiwongs R, Shabunthom R. (2008). A comparison of EQ-5D index scores using the UK, US, and Japan preference weights in a Thai sample with type 2 diabetes. Health Qual Life Outcomes.
149 Savli H, Sevinc A. (2005). The evaluation of the Turkish version of the Well-being Questionnaire (WBQ-22) in patients with Type 2 diabetes: The effects of diabetic complications. J Endocrinol Invest.
150 Scott IU, Smiddy WE, Schiffman J, Feuer WJ, et al. (1999). Quality of life of low-vision patients and the impact of low-vision services. Am J Ophthalmol.
151 Shah SM, Nguyen QD, Sy JP, Ianchulev. (2011). The RIDE and RISE Studies of the Efficacy and Safety of Intravitreal Ranibizumab (LUCENTISA(R)) in Clinically Significant Macular Edema With Center Involvement Secondary to Diabetes Mellitus. IOVS.
152 Shah VA, Gupta SK, Shah KV, Vinjamaram S, et al. (2004). TTO utility scores measure quality of life in patients with visual morbidity due to diabetic retinopathy or ARMD. Ophthalmic Epidemiol.
153 Sharma S, Oliver-Fernandez A, Bakal J, Hollands H, et al. (2003). Utilities associated with diabetic retinopathy: Results from a Canadian sample. Evid Based Eye Care.
154 Sibay TM, Elder JR, Hausler HR. (1971). Incidence of diabetic retinopathy among the mentally ill. Can J Ophthalmol.
155 Slawson D. (2000). How often should patients with type 2 diabetes mellitus be screened for retinopathy?. Evid Based Pract.
156 Smith AF. (2001). The economic impact of ophthalmic services for persons with diabetes in the Canadian Province of Nova Scotia: 1993-1996. Ophthalmic Epidemiol.
157 Sullivan LM, Dukes KA, Harris L, Dittus RS, et al. (1995). A comparison of various methods of collecting self-reported health outcomes data among low-income and minority patients. Med Care.
158 Sultan S, Heurtier-Hartemann A. (2001). Coping and distress as predictors of glycemic control in diabetes. J Health Psychol.
159 Sultan S, Luminet O, Hartemann A. (2010). Cognitive and anxiety symptoms in screening for clinical depression in diabetes A systematic examination of diagnostic performances of the HADS and BDI-SF. J Affective Disord.
160 Suzuki A, Fujiya A, Kiyota A, Yamauchi M, et al. (2007). Approach and long-term process of a clinical network for diabetes involving a hospital which plays the central role in an area: The ogaki diabetic clinical network study. J Jpn Diabetes Soc.
161 Tabaei BP, Shillnovak J, Brandle M, Burke R, et al. (2004). Glycemia and the quality of well-being in patients with diabetes. Qual Life Res.
162 Takahashi Y, Hirata Y. (1983). A follow-up study of painful diabetic neuropathy: physical and psychological aspects. Tohoku J Exp Med.
163 Tapp RJ, Dunstan DW, Phillips P, Tonkin A, et al. (2006). Association between impaired glucose metabolism and quality of life: results from the Australian diabetes obesity and lifestyle study. Diabetes Res Clin Pract.
164 Tsuruoka M, Yamamoto S, Tsukahara I, Akabane N, et al. (2000). A review of the low-vision clinic at Toho University Sakura Hospital. Folia Ophthalmol Jpn.
165 Upton LR. (1990). Coping with stress: Adjustment to visual loss in diabetes mellitus.
166 Van Schaik HJ, itez del Castillo JM, Caubergh MJ, Gobert A, et al. (1998). Evaluation of diabetic retinopathy by fluorophotometry. European concerted action on ocular fluorometry. Int Ophthalmol.
167 Varma R, Paz SH, Azen SP, Klein R, et al. (2004). The Los Angeles Latino Eye Study: design, methods, and baseline data. Ophthalmology.
168 Veglio M, Borra M, Stevens LK, Fuller JH, et al. (1999). The relation between QTc interval prolongation and diabetic complications. The EURODIAB IDDM Complication Study Group. Diabetologia.
169 Vestgaard M, Ringholm L, Laugesen CS, Rasmussen KL, et al. (2010). Pregnancy-induced sight-threatening diabetic retinopathy in women with Type 1 diabetes. Diabet Med.
170 Vileikyte L, Peyrot M, Gonzalez JS, Rubin RR, et al. (2009). Predictors of depressive symptoms in persons with diabetic peripheral neuropathy: A longitudinal study. Diabetologia.
171 Waldhausl W. (1972). Stimulation of immunoreactive insulin and human growth hormone release by administration of arginine in patients with diabetic retinopathy. Acta Endocrinol (Copenh).
172 Wandell PE, Tovi J. (2000). The quality of life of elderly diabetic patients. J Diabetes Complications.
173 Wang C, Chan CLW, Ng S, Ho AHY. (2008). The impact of spirituality on health-related quality of life among Chinese older adults with vision impairment. Aging Ment Health.
174 Warrian KJ, Lorenzana LL, Lankaranian D, Dugar J, et al. (2010). The assessment of disability related to vision performance-based measure in diabetic retinopathy. Am J Ophthalmol.
175 Wasserman LI, Trifonova EA. (2004). Quality of Life and the Structure of Neurosis-like Symptomatology in Persons with Insulin-Dependent Diabetes Mellitus. Int J Ment Health.
176 West SD, Groves DC, Lipinski HJ, Nicoll DJ, et al. (2010). The prevalence of retinopathy in men with Type 2 diabetes and obstructive sleep apnoea. Diabet Med.
177 Winocour PH, Main CJ, Medlicott G, Anderson DC. (1990). A psychometric evaluation of adult patients with type 1 (insulin-dependent) diabetes mellitus: prevalence of psychological dysfunction and relationship to demographic variables, metabolic control and complications. Diabetes Res.
178 Wolffsohn JS, Cochrane AL, Watt NA. (2000). Implementation methods for vision related quality of life questionnaires. Br J Ophthalmol.
179 Woodcock A, Bradley C, Plowright R, ffytche T, et al. (2004). The influence of diabetic retinopathy on quality of life: interviews to guide the design of a condition-specific, individualised questionnaire: the RetDQoL. Patient Educ Couns.
180 Wulsin LR, Jacobson AM, Rand LI. (1991). Psychosocial correlates of mild visual loss. Psychosom Med.
181 Wulsin LR, Jacobson AM, Rand LI. (1993). Psychosocial adjustment to advanced proliferative diabetic retinopathy. Diabetes Care.
182 Yoshida S, Hirai M, Suzuki S, Awata S, et al. (2009). Neuropathy is associated with depression independently of health-related quality of life in Japanese patients with diabetes. Psychiatry Clin Neurosci.
183 Zhang CX, Tse LA, Ye XQ, Lin FY, et al. (2009). Moderating effects of coping styles on anxiety and depressive symptoms caused by psychological stress in Chinese patients with Type 2 diabetes. Diabet Med.
184 Zhao L. (2005). Intervention effects of music relaxation therapy on the quality of life in patients with diabetic retinopathy. Zhongguo Linchuang Kangfu.
185 Zhao W, Chen Y, Lin M, Sigal RJ. (2006). Association between diabetes and depression: Sex and age differences. Public Health.