# Appendix B Inclusion/Exclusion Form

| Reviewer ID | Ref ID
| Criteria | Decision
1. | Report of Primary Research | □Yes □No □Unsure
2. | Population: Adults (≥18 years) | □Yes □No □Unsure
3. | Population: Diagnosed with diabetic retinopathy or diabetic macular edema or neovascular | □Yes □No □Unsure
4a. | Measurement: Does the study report on the use of a patient-reported HRQL measure (physical, social, emotional, mental function)? | □Yes □No □Unsure
4b. | Measurement: Does the study report on the use of a patient-reported HRQL measure (physical, social, emotional, mental function) in the context of assessing an intervention (with or without a comparator) for DR? | □Yes □No □Unsure
| Reviewer Decision | □Yes □No □Unsure
| CONSENSUS DECISION | □INCLUDE □EXCLUDE
*Flag studies that do not investigate an intervention for DR, but do provide the psychometric properties of a HRQL tool.
| □ Abstract requiring full publication
| □ Requires translation | Specify source language