# Appendix A Search Strategies

## Database: Ovid MEDLINE® <1950 to July 2010>

Search Strategy:

--------------------------------------------------------------

1. exp diabetes mellitus/
2. exp hyperinsulinism/
3. exp hypoglycemia/
4. exp hyperglycemia/
5. exp glycosuria/
6. diabet$.tw
7. mellitus.tw
8. ((non insulin adj depend$ adj3 diabetes mellitus) OR (noninsulin$ adj depend$ adj3 diabetes mellitus)).tw.
9. ((insulin adj depend$ adj3 diabetes mellitus) OR (insulindepend$ adj3 diabetes mellitus)).tw.
10. ((type 1 OR type I) adj2 (diabetes mellitus OR DM)).tw
11. ((type 2 OR type II) adj2 (diabetes mellitus OR DM)).tw
12. (T1DM OR T2DM OR ((T1 OR T2) adj DM)).tw
13. ((maturity OR late) adj onset adj diabet$).tw
14. IDDM.tw
15. NIDDM.tw
16. MODY.tw
17. DM.tw
18. OR/1-17 (392,571)
19. exp vision disORders/
20. exp diabetic retinopathy/
21. exp retinal detachment/
22. exp retinal degeneration/
23. exp retinal hemORrhage/
24. exp retinal neovascularization/
25. exp retinal vein occlusion/
26. exp epiretinal membrane/
27. exp vitreORetinopathy, proliferative/
28. exp vitreous detachment/
29. exp vitreous hemORrhage/
30. exp macular edema/
31. (eye disease$ OR blindness OR visual loss$).tw
32. (vis$ adj funct$).tw
33. (retinopath$ OR retinitis OR maculopath$).tw
34. (diabet$ adj3 maculopath$).tw
35. macula$ adj $edema.tw
36. macula$ adj (defect$ OR degenerat$ OR swell$).tw
37. microaneurysm$.tw
38. neovascular$.tw
39. OR/19-38 (142,484)
40. 18 AND 39 (23,376)
41. exp “quality of life”/
42. exp quality-adjusted life years/
43. exp health status/
44. exp health status indicatORs/
45. exp “value of life”/
46. exp self concept/
47. exp “activities of daily living”/
48. exp “severity of illness index”/
49. exp sickness impact profile/
50. exp patient satisfaction/
51. exp questionnaires/
52. “quality of life”.tw
53. “health related quality of life”.tw
54. (health adj status).tw
55. (QoL OR QL).tw
56. QALY.tw
57. HRQL.tw
58. (life adj3 qualit$).tw
59. (funct$ adj (assess$ OR abilit$)).tw
60. “patient repORted outcomes”.tw
61. ADL$.tw
62. OR/41-61 (607,847)
63. SF?36.tw
64. SF?12.tw
65. EuroQol.tw
66. “Quality of Well-Being”.tw
67. “National Eye Institute Visual Functioning Questionnaire”.tw
68. “Visual Function Index”.tw
69. “Activities of Daily Vision”.tw
70. “Daily Living Tasks Dependent on Vision”.tw
71. “sickness impact profile”.tw
72. RAND?36.tw
73. RAND?12.tw
74. “health utilities index”.tw
75. “quality of well-being scale”.tw
76. ”standard gamble”.tw
77. “time-trade off”.tw
78. WHO-BREF.tw
79. “diabetes health profile”.tw
80. “diabetes quality of life”.tw
81. “diabetes quality of life clinical trial questionnaire”.tw
82. “well-being questionnaire”.tw
83. OR 63-82 (4,196)
84. exp depression/
85. exp anxiety/
86. exp anxiety disORders/
87. exp mental disORders/
88. exp mental health/
89. exp mental fatigue/
90. exp stress, psychological/
91. exp social behaviOR/
92. “life stress”.tw
93. anxiet*.tw
94. depress*.tw
95. nervous*.tw
96. (coping adj2 strateg*).tw
97. psychosocial*.tw
98. psychological*.tw
99. (mental adj health).tw
100. (social adj2 (skill* OR behavi?OR)).tw
101. OR/84-100 (1,352,438)
102. 62 OR 83 OR 101 (1,789,878)
103. 40 AND 102 (1,731)

## Database: Ovid EMBASE® <1980 to July 2010>

Search Strategy:

--------------------------------------------------------------

1. exp diabetes mellitus/
2. exp hyperinsulinism/
3. exp hypoglycemia/
4. exp hyperglycemia/
5. exp glycosuria/
6. diabet$.tw
7. mellitus.tw
8. ((non insulin adj depend$ adj diabetes mellitus) OR (noninsulin$ adj depend$ adj diabetes mellitus)).tw.
9. (insulin adj depend$ adj diabetes mellitus).tw.
10. ((type 1 OR type I) adj (diabetes mellitus OR DM)).tw
11. ((type 2 OR type II) adj (diabetes mellitus OR DM)).tw
12. (T1DM OR T2DM OR ((T1 OR T2) adj DM)).tw
13. ((maturity OR late) adj onset adj diabet$).tw
14. IDDM.tw
15. NIDDM.tw
16. MODY.tw
17. DM.tw
18. OR/1-17 (508,740)
19. exp visual disORder/
20. exp diabetic retinopathy/
21. exp retina detachment/
22. exp retina degeneration/
23. exp retina hemORrhage/
24. exp retinal neovascularization/
25. exp retinal vein occlusion/
26. exp vitreORetinopathy
27. exp vitreous body detachment/
28. exp vitreous hemORrhage/
29. (eye disease$ OR blindness OR visual loss$).tw
30. (vis$ adj funct$).tw
31. (retinopath$ OR retinitis OR maculopath$).tw
32. macula$ adj $edema.tw
33. macula$ adj (defect$ OR degenerat$ OR swell$).tw
34. microaneurysm$.tw
35. neovascular$.tw
36. OR/19-35 (270,247)
37. 18 AND 36 (33,026)
38. exp “quality of life”/
39. exp quality adjusted life year/
40. exp health status/
41. exp health survey/
42. exp self concept/
43. exp daily life activity/
44. exp Sickness Impact Profile/
45. exp patient satisfaction/
46. exp questionnaire/
47. “quality of life”.tw
48. “health related quality of life”.tw
49. (health adj status).tw
50. (QoL OR QL).tw
51. QALY.tw
52. HRQL.tw
53. (life adj3 qualit$).tw
54. (funct$ adj (assess$ OR abilit$)).tw
55. “patient repORted outcomes”.tw
56. ADL$.tw
57. health status indicatOR$.tw
58. value of life.tw
59. act$ of daily living.tw
60. (severity adj3 (illness index OR disease index)).tw
61. OR/38-60 (465,498)
62. exp ShORt FORm36/
63. exp ShORt FORm12.tw
64. exp National Eye Institute Visual Functioning Questionnaire/
65. EuroQol.tw
66. quality of well-being.tw
67. visual function index.tw
68. activities of daily vision.tw
69. daily living tasks dependent on vision.tw
70. RAND-36.tw
71. RAND-12.tw
72. health utilities index.tw
73. quality of well-being scale.tw
74. standard gamble.tw
75. time-trade off.tw
76. WHO-BREF.tw
77. diabetes health profile.tw
78. diabetes quality of life.tw
79. diabetes quality of life clinical trial questionnaire.tw
80. well-being questionnaire.tw
81. OR/62-80 (9,399)
82. exp depression/
83. exp anxiety/
84. exp anxiety disORders/
85. exp mental health/
86. exp life stress/
87. exp coping behaviOR/
88. depress$.tw
89. anxiety$.tw
90. nervous$.tw
91. (coping adj2 strateg$).tw
92. psychosocial$.tw
93. psychological$.tw
94. (mental adj health).tw
95. (social adj2 (skill$ OR behavi?OR)).tw
96. OR/82-95 (793,003)
97. 61 OR 81 OR 96 (1,396,857)
98. 37 AND 97 (2,979)

## Database: Ovid PsychINFO <1806 to July 2010>

Search Strategy:

--------------------------------------------------------------

1. exp diabetes mellitus/
2. exp hypoglycemia/
3. exp hyperglycemia/
4. diabet$.tw
5. mellitus.tw
6. ((non insulin adj depend$ adj3 diabetes mellitus) OR (noninsulin$ adj depend$ adj3 diabetes mellitus)).tw.
7. (insulin adj depend$ adj3 diabetes mellitus).tw.
8. ((type 1 OR type I) adj2 (diabetes mellitus OR DM)).tw
9. ((type 2 OR type II) adj2 (diabetes mellitus OR DM)).tw
10. (T1DM OR T2DM OR ((T1 OR T2) adj DM)).tw
11. ((maturity OR late) adj onset adj diabet$).tw
12. IDDM.tw
13. NIDDM.tw
14. MODY.tw
15. DM.tw
16. hyperinsulinism.tw
17. glycosuria.tw
18. OR/1-17 (13,235)
19. exp vision disORders/
20. (eye disease$ OR blindness OR visual loss$).tw
21. (vis$ adj funct$).tw
22. (retinopath$ OR retinitis OR maculopath$).tw
23. (diabet$ adj3 maculopath$).tw
24. macula$ adj $edema.tw
25. macula$ adj (defect$ OR degenerat$ OR swell$).tw
26. microaneurysm$.tw
27. neovascular$.tw
28. (diabet$ adj3 retinopath$).tw
29. (retina$ adj3 detach$).tw
30. (retina$ adj3 degenerat$).tw
31. (retina$ adj3 h$emORrhage).tw
32. (retina$ adj3 neovasculari*ation).tw
33. (retina$ adj3 vein occlusion).tw
34. epiretinal membrane.tw
35. vitreORetinopathy.tw
36. (vitreous adj3 (detach$ OR h?emORrhage)).tw
37. OR/19-36 (17,045)
38. 18 AND 37 (323)
39. exp “quality of life”/
40. exp life satisfaction/
41. exp self concept/
42. exp “activities of daily living”/
43. exp client satisfaction/
44. exp questionnaires/
45. “quality of life”.tw
46. “health related quality of life”.tw
47. (health adj status).tw
48. (QoL OR QL).tw
49. QALY.tw
50. HRQL.tw
51. (life adj3 qualit$).tw
52. (funct$ adj (assess$ OR abilit$)).tw
53. “patient repORted outcomes”.tw
54. ADL$.tw
55. (health adj3 (status OR status indicatOR$)).tw
56. value of life.tw
57. (severity adj3 (illness index OR disease index)).tw
58. sickness impact profile.tw
59. OR/39-58 (116,240)
60. SF–36.tw
61. SF–12.tw
62. EuroQol.tw
63. Quality of Well-Being.tw
64. National Eye Institute Visual Functioning Questionnaire.tw
65. Visual Function Index.tw
66. Daily Living Tasks Dependent on Vision.tw
67. RAND-36.tw
68. RAND-12.tw
69. health utilities index.tw
70. quality of well-being scale.tw
71. standard gamble.tw
72. time-trade off.tw
73. WHO-BREF.tw
74. diabetes health profile.tw
75. diabetes quality of life.tw
76. diabetes quality of life clinical trial questionnaire.tw
77. well-being questionnaire.tw
78. OR 60-77 (3,135)
79. 59 OR 78 (116,961)
80. exp majOR depression/
81. exp anxiety/
82. exp anxiety disORders/
83. exp mental health/
84. exp mental disORders/
85. exp stress, psychological/
86. exp coping behaviOR/
87. “life stress”.tw
88. anxiet*.tw
89. depress*.tw
90. nervous*.tw
91. (coping adj2 strateg*).tw
92. psychosocial*.tw
93. psychological*.tw
94. (mental adj health).tw
95. (social adj2 (skill* OR behavi?OR)).tw
96. OR/80-95 (795,694)
97. 79 OR 96 (866,765)
98. 38 AND 97 (113)

## Database: Ovid Cochrane Central Register of Control Trials <1991 to July 2010>

Search Strategy:

--------------------------------------------------------------

1. exp diabetes mellitus/
2. exp hyperinsulinism/
3. exp hypoglycemia/
4. exp hyperglycemia/
5. exp glycosuria/
6. diabet$.tw
7. mellitus.tw
8. ((non insulin adj depend$ adj3 diabetes mellitus) OR (noninsulin$ adj depend$ adj3 diabetes mellitus)).tw.
9. (insulin adj depend$ adj3 diabetes mellitus).tw.
10. ((type 1 OR type I) adj2 (diabetes mellitus OR DM)).tw
11. ((type 2 OR type II) adj2 (diabetes mellitus OR DM)).tw
12. (T1DM OR T2DM OR ((T1 OR T2) adj DM)).tw
13. ((maturity OR late) adj onset adj diabet$).tw
14. IDDM.tw
15. NIDDM.tw
16. MODY.tw
17. DM.tw
18. OR/1-17 (21,104)
19. exp vision disORders/
20. exp diabetic retinopathy/
21. exp retinal detachment/
22. exp retinal degeneration/
23. exp retinal hemORrhage/
24. exp retinal neovascularization/
25. exp retinal vein occlusion/
26. exp epiretinal membrane/
27. exp vitreORetinopathy, proliferative/
28. exp vitreous detachment/
29. exp vitreous hemORrhage/
30. exp macular edema/
31. (eye disease$ OR blindness OR visual loss$).tw
32. (vis$ adj funct$).tw
33. (retinopath$ OR retinitis OR maculopath$).tw
34. (diabet$ adj3 maculopath$).tw
35. macula$ adj $edema.tw
36. macula$ adj (defect$ OR degenerat$ OR swell$).tw
37. microaneurysm$.tw
38. neovascular$.tw
39. OR/19-38 (4,902)
40. 18 AND 39 (1,377)
41. exp “quality of life”/
42. exp quality-adjusted life years/
43. exp health status/
44. exp health status indicatORs/
45. exp “value of life”/
46. exp self concept/
47. exp “activities of daily living”/
48. exp “severity of illness index”/
49. exp sickness impact profile/
50. exp patient satisfaction/
51. exp questionnaires/
52. “quality of life”.tw
53. “health related quality of life”.tw
54. (health adj status).tw
55. (QoL OR QL).tw
56. QALY.tw
57. HRQL.tw
58. (funct$ adj (assess$ OR abilit$)).tw
59. “patient repORted outcomes”.tw
60. ADL$.tw
61. OR/41-61 (44,357)
62. SF–36.tw
63. SF–12.tw
64. EuroQol.tw
65. “Quality of Well-Being”.tw
66. “National Eye Institute Visual Functioning Questionnaire”.tw
67. “Visual Function Index”.tw
68. “Activities of Daily Vision”.tw
69. Daily Living Tasks Dependent on Vision.tw
70. sickness impact profile.tw
71. RAND-36.tw
72. health utilities index.tw
73. quality of well-being scale.tw
74. standard gamble.tw
75. time-trade off.tw
76. WHO-BREF.tw
77. diabetes health profile.tw
78. diabetes quality of life.tw
79. diabetes quality of life clinical trial questionnaire.tw
80. well-being questionnaire.tw
81. OR/62-80 (2,457)
82. 62 OR 81 (44,449)
83. exp depression/
84. exp anxiety/
85. exp anxiety disORders/
86. exp mental disORders/
87. exp mental health/
88. exp mental fatigue/
89. exp stress, psychological/
90. exp social behaviOR/
91. “life stress”.tw
92. anxiet*.tw
93. depress*.tw
94. nervous*.tw
95. (coping adj2 strateg*).tw
96. psychosocial*.tw
97. psychological*.tw
98. (mental adj health).tw
99. (social adj2 (skill* OR behavi?OR)).tw
100. OR/93-99 (64,320)
101. 82 OR 100 (96,404)
102. 40 AND 101 (71)

## Database: CINAHL Plus with full text <1937 to July 2010>

Search Strategy:

--------------------------------------------------------------

- S108=S46 AND S107 (1,651)
- S107=S67 OR S88 OR S106 (593,052)
- S106=S89 OR S90 OR S91 OR S92 OR S93 OR S94 OR S95 OR S96 OR S97 OR S98 OR S99 OR S100 OR S101 OR S102 OR S103 OR S104 OR S105 (552,364)
- S105=TX coping N2 strateg*
- S104=TX social N2 behavi#OR
- S103=TX social N2 skill*
- S102=TX mental N1 health
- S101=TX psychological*
- S100=TX psychosocial*
- S99=TX nervous*
- S98=TX depress*
- S97=TX anxiet*
- S96=TX “life stress”
- S95=TX “life stress”
- S94=MH “Social BehaviOR+”
- S93=MH “Stress, Psychological+”
- S92=MH “Mental Health”
- S91=MH “Mental DisORders+”
- S90=MH “Anxiety DisORders+”
- S89=MH “Anxiety+”
- S88=S68 OR S69 OR S70 OR S71 OR S72 OR S73 OR S74 OR S75 OR S76 OR S77 OR S78 OR S79 OR S80 OR S81 OR S82 OR S83 OR S84 OR S85 OR S86 OR S87 (33,010)
- S87=TX “well-being questionnaire”
- S86=TX “diabetes quality of life clinical trial questionnaire”
- S85=TX “diabetes quality of life”
- S84=TX “diabetes health profile”
- S83=TX WHO-BREF
- S82=TX “time-trade off”
- S81=TX “standard gamble”
- S80=TX “quality of well-being scale”
- S79=TX” health utilities index”
- S78=TX RAND#12
- S77=TX RAND#36
- S76=TX “sickness impact profile”
- S75= TX “activities of daily vision”
- S74= TX “visual function index”
- S73=TX “national eye institute visual functioning questionnaire”
- S72=TX “quality of well-being”
- S71=TX EuroQoL
- S70=TX sf#12
- S69=TX sf#36
- S68=MH “Severity of Illness Indices+”
- S67=S47 OR S48 OR S49 OR S50 OR S51 OR S52 OR S53 OR S54 OR S55 OR S56 OR S57 OR S58 OR S59 OR S60 OR S61 OR S62 OR S63 OR S64 OR S65 OR S66 (310,508)
- S66=TX ADL*
- S65=TX “patient reported outcomes”
- S64=TX (funct* N1 assess*) OR (funct* abilit*)
- S63=TX life N3 qualit*
- S62=TX HRQL
- S61=TX QALY
- S60=TX QoL
- S59=TX (health N1 status)
- S58=TX “health related quality of life”
- S57=TX “quality of life”
- S56=MH “Questionnaires+”
- S55=MH “Patient Satisfaction”
- S54=MH “Sickness Impact Profile”
- S53=MH “Severity of Illness”
- S52=MH “Activities of Daily Living+”
- S51=MH “Self Concept+”
- S50=MH “Health Status IndicatORs”
- S49=MH “Health Status+”
- S48=MH “Quality-Adjusted Life Years”
- S47=MH “Quality of Life+”
- S46=S21 AND S45 (4,823)
- S45=S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40 OR S41 OR S42 OR S43 OR S44 (19,362)
- S44=TX vitreous h#emORrhage
- S43=TX vitreous detach*
- S42=TX vitreORetinopathy
- S41=TX epiretinal membrane
- S40=TX retina* N1 neovasculari?ation
- S39=TX retina* N1 vein occlusion
- S38=TX retina* N1 detach*
- S37=TX retina* N1 degenerat*
- S36=TX microaneurysm*
- S35=TX neovascular*
- S34=TX macula* N1 swell*
- S33=TX macula* N1 degenerat*
- S32=TX macula* N1 defect*
- S31=TX macula* N1 #edema
- S30=TX (diabet* N3 maculopath*)
- S29=TX (retinopath* OR blindness OR visual loss*)
- S28=TX (vis* N1 funct*)
- S27=TX (eye disease* OR blindeness OR visual loss*)
- S26=MH “Retinal Diseases+”
- S25=MH “Eye HemORrhage”
- S24=MH “Retinal Detachment”
- S23=MH “Diabetic Retinopathy”
- S22=MH “Vision DisORders+”
- S21=S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 OR S20 (161,039)
- S20=TX DM
- S19=TX MODY
- S18=TX NIDDM
- S17=TX IDDM
- S16=TX ((maturity onset N2 diabet*) OR (late onset N2 diabet*))
- S15=TX (T1 N1 DM) OR (T2 N1 DM)
- S14=TX (T1DM OR T2DM)
- S13=TX (type II N2 diabetes mellitus) OR (type II N2 DM)
- S12=TX (type 2 N2 diabetes mellitus) OR (type 2 N2 DM)
- S11=TX (type I N2 diabetes mellitus) OR (type I N2 DM)
- S10=TX ((type 1 N2 diabetes mellitus) OR (type 1 N2 DM))
- S9=TX (insulin N1 depend* N3 diabetes mellitus)
- S8=TX ((non insulin N1 depend* N3 diabetes mellitus) OR (noninsulin* N1 depend* N3 diabetes mellitus))
- S7=TX mellitus
- S6=TX diabet*
- S5=TX glycosuria
- S4=MH Hypoglycemia+
- S3=MH Hyperglycemia+
- S2=MH Hyperinsulinism+
- S1=MH Diabetes Mellitus+

## Database: Scopus <1823 to July 2010>

Search Strategy:

--------------------------------------------------------------

((TITLE-ABS-KEY(“diabetes PRE/1 mellitus”) OR (diabet*) OR (mellitus)) AND (TITLE-ABS-KEY(“diabetic PRE/1 retinopath*”) OR (blindness) OR (“visual PRE/1 loss*”) OR (“vis* PRE/1 funct*”) OR (retinopath*) OR (retinitis) OR (maculopath*) OR (“macula* PRE/1 defect*”) OR (“macula* PRE/1 degenerat*”) OR (“macula* PRE/1 swell*”)) AND ((TITLE-ABS-KEY(“quality PRE/1 life”) OR (“health PRE/1 status”) OR (“value PRE/1 life”) OR (“self PRE/1 concept”) OR (“activities PRE/1 daily living”) OR (“sickness impact profile”) OR (“patient PRE/1 satisfaction”) OR (“patient PRE/1 repORted outcome*”)) OR (TITLE-ABS-KEY(depression) OR (anxiety) OR (“anxiety PRE/1 disORder*”) OR (“mental PRE/1 disORder*”) OR (“mental PRE/1 health”) OR (“mental PRE/1 fatigue”) OR (“coping PRE/1 strateg*”)))) (1,244)

Database: Clinicaltrials.gov, Results <April 2011>

NCT Number | Title | Study Condition | Intervention | HRQL measure
NCT01131585 | Safety and efficacy of ranibizumab in diabetic macular edema | Diabetic macular edema; proliferative diabetic retinopathy | Ranibizumab + laser; sham injections + laser | Unspecified QOL
NCT00701181 | Prospective, randomized, multicenter, comparator study evaluating efficacy and safety of PF-04523655 versus laser in subjects with diabetic macular edema | Diabetic retinopathy; diabetes complications | Laser treatment; PF-04523655 (high dose); PF-04523655 (middle dose); PF-04523655 (low dose) | VFQ–25
NCT00090519 | Reduction in the occurrence of center-involved diabetic macular edema | Diabetic retinopathy | Ruboxistaurin; placebo | VFQ–25
NCT00799227 | Safety and efficacy of a new treatment in vitrectomized subjects with diabetic macular edema | Diabetic macular edema | Dexamethasone | VFQ–25
NCT00464685 | Safety and efficacy of a new treatment in combination with laser for diabetic macular edema | Diabetic macular edema | Dexamethasone; sham injection | Unspecified QOL
NCT00168389 | A study of the safety and efficacy of a new treatment for diabetic macular edema | Diabetic macular edema | Dexamethasone; sham dexamethasone | Unspecified QOL
NCT01171976 | Efficacy and safety of Ranibizumab in two “treat and extend” treatment algorithms versus Ranibizumab as needed in patients with macular edema and visual impairment secondary to diabetes mellitus (RETAIN) | Diabetic macular edema | Ranibizumab | VFQ-25
NCT00473382 | A study of ranibizumab injection in subjects with clinically significant macular edema with center involvement secondary to diabetes mellitus (RIDE) | Diabetes mellitus macular edema | Ranibizumab; sham | VFQ–25
NCT00473330 | A study of ranibizumab injection in subjects with clinically significant macular edema with center involvement secondary to diabetes mellitus (RISE) | Diabetes mellitus macular edema | Ranibizumab; sham | VFQ–25
NCT00989989 | Efficacy and Safety of Ranibizumab (Intravitreal Injections) in Patients With Visual Impairment Due to Diabetic Macular Edema | Diabetic macular edema | Ranibizumab; Laser photocoagulation | Unspecified PROs
NCT01292798 | Treatment of Residual Diabetic Macular Edema With Ranibizumab | Diabetic macular edema | Ranibizumab | Participant scores on unspecified work productivity and activity impairment questionnaire
NCT01318941 | Observe the effectiveness and safety of Ranibizumab in real life setting | Wet age-related macular degeneration, diabetic macular edema, retinal vein occlusion | Ranibizumab | VFQ–25
NCT01331681 | VEGF Trap-Eye in vision impairment due to diabetic macular edema (DME) | Diabetes mellitus; macular edema | VEGF Trap-Eye (BAY86-5321); VEGF Trap-Eye (BAY86-5321); Laser treatment | Unspecified QOL