# Abbreviations and Acronyms

95% CI: 95% confidence intervals
ADVS: Activities of Daily Vision Scale
BVCA: best corrected visual acuity
CONSORT: Consolidated Standards of Reporting Trials
COSMIN: COnsensus-based Standards for the selection of health Measurement Instruments
DME: diabetic macular edema
DR: diabetic retinopathy
DTSQ: Diabetic Treatment Satisfaction Questionnaire
dx: diagnosis
ETDRS: Early Treatment of Diabetic Retinopathy Study
HRQL: health-related quality of life
ICC: interclass correlation coefficient
logMAR: logarithm of minimal angle of resolution
MCS: mental component summary
MD: mean differences
mo: month
MOS: Medical Outcomes Study
NOS: Newcastle-Ottawa Scale
NPDR: nonproliferative diabetic retinopathy
NRCT: nonrandomized controlled trial
PCS: physical component summary
PDR: proliferative diabetic retinopathy
PRO: patient reported outcomes
Pt: patient
QOL: quality of life
RCT: randomized controlled trial
RetTSQ: Diabetic Retinopathy Treatment Satisfaction Questionnaire
RetDQoL: Diabetic Retinopathy Dependent Quality of Life
SES: socioeconomic status
SF–36: Short-Form Health Survey 36
SIP: Sickness Impact Profile
tx: treatment
UK: United Kingdom
US: United States
VA: visual acuity
VF: visual function
VF–14: Visual Function–14
VFQ–25: National Eye Institute Visual Function Questionnaire–25
yr: year