# RESULTS

## Projected Undiscounted Outcomes with Screening

Undiscounted outcomes associated with the screening strategies are presented in Table 8A for the MISCAN model, Table 8B for the SimCRC model, and Table 8C for the CRC-SPIN model. Without screening we project that 53 to 60 out of every 1000 65-year old individuals will be diagnosed with CRC in their lifetimes. This induces approximately $3 to $4 million in lifetime direct medical costs ($57 to $71 thousand per CRC case). With screening and removal of adenomas that may have become cancer over time, many of these CRC cases can be prevented assuming 100% adherence to screening regiments; the reduction in the lifetime risk of CRC ranged from 32–49% with annual FOBT (Hemoccult II) screening to 53–85% with 10-year colonoscopy screening (reported ranges reflect differences in projections by model). Some of the benefit associated with the fecal-related tests is a result of the false-positive rate, which leads to individuals being placed on a colonoscopy schedule. In other words, some of the benefit of these tests can be attributed to the fact that a substantial number of individuals with false-positive test results subsequently undergo screening with 10-year colonoscopy. In the MISCAN model the combination of 5-yearly flexible sigmoidoscopy with an annual highly sensitive FOBT (Hemoccult SENSA or immunochemical) is the most effective strategy in terms of life-years gained compared with no screening, saving 154 life-years per 1000 persons screened. In the SimCRC and CRC-SPIN models, 10-yearly colonoscopy is most effective, saving 171 and 185 life-years per 1000 persons screened, respectively. Five-yearly CT colonography with a 6mm referral threshold and the most optimistic test characteristics (i.e., Department of Defense study) resulted in 2–7 fewer life-years gained per 1000 individuals compared with 10-yearly colonoscopy, with an increase in lifetime (undiscounted) costs of approximately $600,000–$700,000 per 1000.

## Cost-Effectiveness Analysis from Payer Perspective

Table 9 shows the total discounted costs, discounted life-years gained, and the incremental cost-effectiveness ratios for a cohort of 65-year-olds by screening strategy, including no screening, for each model (results for a cohort of 50-year-olds are presented in Appendix 5). Note that the incremental cost-effectiveness ratios were calculated using each CT colonography strategy in turn as they are not competing options. The models varied somewhat as to which tests were on the efficient frontier (i.e., were not ruled out by simple or extended dominance). Strategies on the efficient frontier are those strategies with an associated incremental cost-effectiveness ratio and are potentially cost-effective depending on the societal willingness to pay for a life-year gained. All three models showed the CT colonography strategies to be the most costly options. Figure 2 shows the plots of the discounted life-years gained (compared with no screening), the discounted lifetime direct medical costs (from the Medicare perspective), and the cost-efficient frontier, where each non-dominated strategy is compared with the next least expensive strategy. Hemoccult II was cost-saving compared with no screening for all models. This was the only cost-saving strategy in the MISCAN model. For SimCRC and CRC-SPIN, however, all non-CT colonography strategies were cost-saving compared with no screening. That CT colonography strategies were the most costly can be easily seen from Figure 2 since for all three models the CT colonography strategies lie to the far right of all screening strategies. Also the CT colonography strategies are more expensive and with fewer life years gained compared to optical colonoscopy for all 3 microsimulation models. Although CT colonography is dominated by the currently recommended screening options, the costs per life-year gained compared to no screening are below $10,000 per life-year gained for both base cases and all three models (Appendix 3).

## Threshold Analyses

CT colonography generally costs less than optical colonoscopy on a per scan basis but the overall screening strategy for CT colonography screening is more expensive than other screening strategies in general as demonstrated here given comparable adherence. At a cost per test of $488, none of the CT colonography strategies were on the efficient frontier (Figure 2). Table 10 shows the threshold CT colonography costs under the two base-case scenarios. Threshold analyses indicated that in order for the base-case 5-yearly CT colonography strategies with a 6mm referral threshold to be on the efficient frontier, a CT scan would need to cost between $108 and $205 (depending on the test characteristics and the simulation model used). The range of threshold costs required for CT colonography screening to be on the efficient frontier was wider when considering 10-yearly CT colonography strategies with a 6mm threshold, ranging from $103 to $371. Table 10 also presents threshold costs for CT colonography to reach the efficient frontier under different scenarios of the test characteristics for CT colonography (worst-case assumption and 2D reading from the Department of Defense study) with screening interval of 5 years. The threshold costs were much lower than the base-case values, while the 2D Department of Defense analysis was more consistent with the base-case analysis, although the range was wider. Figures 3 and 4 illustrate threshold cost values graphically with a 6mm referral and a 10 mm referral respectively.

Appendix 4 also reports the secondary analyses where different criteria were used to calculate the CT scan cost thresholds. Note, that the primary analysis represents the theoretically correct analysis (62). The threshold costs tended to be slightly higher to be cost-neutral compared to no screening. In order for the base-case CT colonography strategies (i.e., 5-yearly screening with a 6mm referral threshold) to have the same average cost-effectiveness ratio (ACER) compared with no screening as the colonoscopy strategy, a CT scan would have to cost between $179 and $237 (depending upon the CT colonography test characteristics and the model used).

## Sensitivity Analyses

The threshold costs associated with varying the test characteristics for CT colonography strategies with a 10 mm colonoscopy referral threshold are shown in Table 11. Threshold analyses indicated that in order for 5-yearly CT colonography with a 10mm referral threshold to be on the efficient frontier, a CT colonography scan would need to cost in the range of $98 to $192 for primary 3D reads, $49 to $135 for mixed 2D and 3D reads, and $73 to $160 for primary 2D reads (depending on the test characteristics and the simulation model used). Using the secondary criteria to determine thresholds (Appendix 4), the threshold costs tended to be slightly higher than the primary analysis (i.e., on the efficient frontier). In no case was the threshold cost greater than the base-case unit cost estimate of $488.

If individuals who would not be screened otherwise would get screened with CT colonography, its cost-effectiveness would improve. The threshold costs for the test to lie on the efficient frontier under varying adherence assumptions are shown in Table 12. With a 10% improvement in CT colonography screening adherence compared with other tests (i.e., 10% of otherwise unscreened persons adopt CT colography screening), the CT colonography cost threshold for being on the efficient frontier increased to $293–$408. With a 25% improvement in CT colonography screening adherence compared with other tests (i.e., 62.5% overall adherence), the CT colonography cost threshold for being on the efficient frontier increased to $547–$694.

Table 13 contains the results of the threshold analysis from a modified societal perspective. From this perspective the threshold costs that result in a CT colonography strategy reaching the efficient frontier are $154–$336 for the 5-yearly testing with a 6 mm referral threshold. These thresholds costs are a bit higher than those from the payer perspective. The higher frequency of Hemoccult II and Hemoccult SENSA scenarios results in considerably higher additional time costs than with CT screening, allowing for higher per-test costs for the CT colonography scan. The total threshold costs from a modified societal perspective include co-payments and patient time costs. To obtain CMS payment rates the co-payments and patient time costs should be subtracted from the total threshold costs. Assuming no co-payments and patient time costs of $17 per hour yields CMS payment rates of $26–$181 for 5-yearly CT colonography screening with a 6mm referral threshold.

All analyses were conducted for the Medicare population aged 65 years and older assuming no prior CRC screening among this group. To assess the effect of this assumption, we evaluated the cost-effectiveness of the 15 screening strategies for a cohort of 50-year-olds, with screening starting at age 50. Results are presented in Appendix 5. The CT colonography strategies remained the most costly of the screening strategies considered. Threshold analyses indicated that in order for 5-yearly CT colonography with a 6mm referral threshold to be on the efficient frontier, a CT scan would need to cost between $72 and $179 (depending on the test characteristics and the simulation model used), which was lower than we found in the analysis of 65-year-old individuals.

Table 14 shows the results of the threshold analysis on the efficient frontier when different percentages of anesthesia costs are included in the cost of colonoscopy. For the MISCAN and SimCRC models the threshold costs for CT colonography decrease by $0 to $8 when including more payment for anesthesia cost, whereas for the CRC-SPIN model the threshold costs increase by $8–$25. We conclude that even when accounting for 100% payment of anesthesia costs, CT colonography payment thresholds only change slightly. The differences in part relate that the models have different referent strategies on the frontier. Colonoscopy strategy is slightly below the efficient frontier for the MISCAN model. Given that colonoscopy is an integral part of all screening programs, the extra anesthesia cost for colonoscopy affects all screening strategies. Hence, we found that the threshold CT colonography costs changed only slightly with the addition of anesthesia, which was primarily because the strategies that were used as a comparator with the CT colonography strategy has similar numbers of colonoscopy requirements over a lifetime.

Table 8A Undiscounted costs by type, number of life-years gained, and number of cases of CRC per 1000 65-year-olds, by screening scenario – MISCAN

Scenario | Costs ($) | | | | | | | Outcomes
Scenario | Screening | Follow-Up | Polyp Resection | Surveillance | Complications | CRC Treatment | Total Costs | LYG | SymDx CRC | ScnDx CRC
No screening | 0 | 0 | 0 | 0 | 0 | 4,030,647 | 4,030,647 | 0 | 57 | 0
HII | 45,577 | 207,470 | 86,984 | 418,620 | 15,647 | 2,927,696 | 3,701,995 | 116.5 | 18 | 21
HS | 31,762 | 370,237 | 125,488 | 693,037 | 26,573 | 2,501,443 | 3,748,541 | 142.8 | 12 | 20
FIT | 178,116 | 318,912 | 116,129 | 614,068 | 23,317 | 2,573,214 | 3,823,757 | 141.0 | 12 | 21
SIGB | 516,641 | 193,530 | 115,568 | 545,450 | 19,110 | 2,415,702 | 3,806,002 | 132.2 | 16 | 14
SIG | 378,703 | 268,592 | 124,815 | 633,967 | 23,143 | 2,371,694 | 3,800,914 | 135.4 | 15 | 15
HII + SIGB | 471,033 | 279,361 | 130,886 | 665,461 | 24,154 | 2,098,139 | 3,669,035 | 149.1 | 11 | 17
HII + SIG | 355,281 | 333,025 | 136,711 | 730,181 | 26,790 | 2,275,248 | 3,857,236 | 149.9 | 11 | 17
HS + SIGB | 344,285 | 398,694 | 145,073 | 819,404 | 30,834 | 2,016,539 | 3,754,829 | 154.1 | 10 | 17
HS + SIG | 262,997 | 422,676 | 147,776 | 854,913 | 32,091 | 2,208,379 | 3,928,832 | 154.1 | 10 | 17
FIT + SIGB | 507,549 | 356,996 | 140,678 | 765,688 | 28,504 | 2,229,174 | 4,028,589 | 154.3 | 10 | 18
FIT + SIG | 402,045 | 391,252 | 144,355 | 811,232 | 30,469 | 2,219,036 | 3,998,390 | 154.3 | 10 | 18
COL | 776,369 | 0 | 152,502 | 677,187 | 36,327 | 2,198,866 | 3,841,252 | 151.6 | 12 | 15
CTC DoD 3D 6mm 5y | 1,007,280 | 354,666 | 135,665 | 748,110 | 27,561 | 2,264,920 | 4,538,212 | 149.5 | 11 | 17
CTC NCTC 2D/3D 6mm 5y | 1,129,911 | 290,386 | 123,520 | 644,144 | 23,369 | 2,375,757 | 4,587,088 | 142.7 | 13 | 17

LYG = life-years gained compared with no screening; SymDx CRC = symptom-detected colorectal cancer; ScnDx CRC = screen-detected colorectal cancer

Table 8B Undiscounted costs by type, number of life-years gained, and number of cases of CRC per 1000 65-year-olds, by screening scenario – SimCRC

Scenario | Costs ($) | | | | | | | Outcomes
Scenario | Screening | Follow-Up | Polyp Resection | Surveillance | Complications | CRC Treatment | Total Costs | LYG | SymDx CRC | ScnDx CRC
No screening | 0 | 0 | 0 | 0 | 0 | 3,540,411 | 3,540,411 | 0 | 60 | 0
HII | 74,558 | 189,224 | 63,882 | 251,236 | 11,119 | 2,213,526 | 2,803,544 | 113.9 | 14 | 21
HS | 121,839 | 359,983 | 100,870 | 409,826 | 20,408 | 1,636,905 | 2,649,832 | 150.7 | 8 | 18
FIT | 248,015 | 305,726 | 91,444 | 371,278 | 17,606 | 1,711,732 | 2,745,801 | 148.3 | 8 | 19
SIGB | 458,414 | 129,774 | 153,495 | 302,136 | 11,130 | 1,795,444 | 2,850,392 | 120.6 | 19 | 10
SIG | 452,330 | 218,999 | 82,962 | 355,829 | 15,267 | 1,684,643 | 2,810,029 | 128.0 | 16 | 10
HII + SIGB | 522,284 | 251,218 | 168,972 | 239,952 | 13,014 | 1,446,187 | 2,641,626 | 157.7 | 7 | 15
HII + SIG | 529,760 | 331,172 | 89,836 | 255,648 | 15,279 | 1,395,290 | 2,616,985 | 160.1 | 7 | 15
HS + SIGB | 437,692 | 388,531 | 171,293 | 417,676 | 21,751 | 1,255,331 | 2,692,275 | 169.3 | 6 | 14
HS + SIG | 444,054 | 442,437 | 114,584 | 431,707 | 23,361 | 1,231,886 | 2,688,030 | 170.2 | 5 | 13
FIT + SIGB | 628,080 | 342,482 | 171,280 | 366,098 | 18,916 | 1,278,827 | 2,805,683 | 168.9 | 6 | 14
FIT + SIG | 638,476 | 405,523 | 107,594 | 379,303 | 20,723 | 1,251,488 | 2,803,107 | 169.9 | 5 | 14
COL | 783,430 | 0 | 137,876 | 598,884 | 32,857 | 1,124,529 | 2,677,576 | 171.3 | 6 | 11
CTC DoD 3D 6mm 5y | 1,115,618 | 348,524 | 114,329 | 500,485 | 23,565 | 1,172,674 | 3,275,196 | 168.2 | 6 | 12
CTC NCTC 2D/3D 6mm 5y | 1,213,047 | 280,882 | 101,516 | 441,470 | 19,842 | 1,288,954 | 3,345,711 | 160.2 | 7 | 12

LYG = life-years gained compared with no screening; SymDx CRC = symptom-detected colorectal cancer; ScnDx CRC = screen-detected colorectal cancer

Table 8C Undiscounted costs by type, number of life-years gained, and number of cases of CRC per 1000 65-year-olds, by screening scenario – CRC-SPIN

Scenario | Costs ($) | | | | | | | Outcomes
Scenario | Screening | Follow-Up | Polyp Resection | Surveillance | Complications | CRC Treatment | Total Costs | LYG | SymDx CRC | ScnDx CRC
No screening | 0 | 0 | 0 | 0 | 0 | 2,999,824 | 2,999,824 | 0 | 53 | 0
HII | 80,263 | 169,980 | 50,324 | 200,706 | 10,036 | 1,663,309 | 2,174,619 | 114.5 | 17 | 12
HS | 135,166 | 353,732 | 83,847 | 337,414 | 19,782 | 1,057,232 | 1,987,173 | 155.1 | 7 | 11
FIT | 267,328 | 293,055 | 74,803 | 302,324 | 16,660 | 1,160,290 | 2,114,460 | 150.4 | 8 | 11
SIGB | 478,290 | 110,463 | 209,824 | 269,120 | 10,365 | 1,211,533 | 2,289,595 | 133.7 | 17 | 4
SIG | 474,358 | 206,889 | 72,375 | 311,882 | 14,770 | 1,079,869 | 2,160,144 | 142.2 | 14 | 5
HII + SIGB | 479,837 | 221,064 | 204,285 | 347,052 | 15,715 | 877,095 | 2,145,048 | 163.7 | 7 | 7
HII + SIG | 476,977 | 289,511 | 86,877 | 373,491 | 18,922 | 813,753 | 2,059,531 | 166.7 | 7 | 7
HS + SIGB | 420,636 | 374,095 | 189,459 | 415,934 | 22,787 | 692,561 | 2,115,471 | 175.9 | 5 | 7
HS + SIG | 425,961 | 404,518 | 100,708 | 426,792 | 24,437 | 666,213 | 2,048,629 | 176.8 | 4 | 7
FIT + SIGB | 581,132 | 320,807 | 194,795 | 394,441 | 20,268 | 729,944 | 2,241,386 | 174.4 | 5 | 7
FIT + SIG | 567,998 | 364,345 | 96,403 | 411,602 | 22,497 | 694,657 | 2,157,501 | 175.8 | 5 | 7
COL | 822,584 | 0 | 118,456 | 506,142 | 33,208 | 496,246 | 1,976,636 | 184.9 | 3 | 5
CTC DoD 3D 6mm 5y | 1,202,218 | 329,204 | 92,468 | 398,610 | 21,994 | 610,307 | 2,654,802 | 177.7 | 5 | 5
CTC NCTC 2D/3D 6mm 5y | 1,287,352 | 258,000 | 83,325 | 363,894 | 18,549 | 686,995 | 2,698,114 | 172.2 | 6 | 5

LYG = life-years gained compared with no screening; SymDx CRC = symptom-detected colorectal cancer; ScnDx CRC = screen-detected colorectal cancer

Table 9 Discounted costs and life-years gained per 1000 65-year-olds without CRC screening and with 14 CRC screening strategies and associated incremental cost-effectiveness ratios

Strategy | MISCAN | | | SimCRC | | | CRC-SPIN
Strategy | Discounted Costs ($) | Discounted LYG | ICER ($) | Discounted Costs ($) | Discounted LYG | ICER ($) | Discounted Costs ($) | Discounted LYG | ICER ($)
No Screening | 2,714,556 | 0 | d | 2,367,514 | 0 | d | 1,976,803 | 0 | d
HII | 2,631,879 | 65.7 | --- | 2,082,788 | 59.9 | d | 1,536,474 | 64.0 | d
HS | 2,715,683 | 81.1 | 5,455 | 2,042,708 | 81.1 | --- | 1,482,449 | 87.3 | ---
FIT | 2,777,228 | 80.1 | d | 2,116,618 | 79.8 | d | 1,574,679 | 84.7 | d
SIGB | 2,823,217 | 75.0 | d | 2,168,782 | 65.2 | d | 1,716,321 | 75.8 | d
SIG | 2,810,249 | 76.7 | d | 2,151,925 | 69.1 | d | 1,626,360 | 80.4 | d
HII + SIGB | 2,790,651 | 84.9 | 19,381 | 2,085,889 | 85.7 | d | 1,656,317 | 92.9 | d
HII + SIG | 2,839,118 | 85.4 | d | 2,072,929 | 87.0 | 5,147 | 1,590,434 | 94.5 | d
HS + SIGB | 2,859,815 | 88.0 | 22,940 | 2,151,806 | 92.5 | d | 1,666,766 | 99.9 | d
HS + SIG | 2,907,440 | 87.9 | d | 2,150,786 | 93.0 | 12,938 | 1,611,331 | 100.5 | d
FIT + SIGB | 3,022,139 | 88.1 | d | 2,244,313 | 92.3 | d | 1,768,508 | 99.2 | d
FIT + SIG | 2,990,860 | 88.1 | 988,660 | 2,244,650 | 92.8 | d | 1,699,373 | 99.9 | d
COL | 2,906,228 | 86.7 | d | 2,173,712 | 93.8 | 27,737 | 1,600,155 | 105.5 | 6,465
CTC DoD 3D 6mm 5y^*^ | 3,469,661 | 85.3 | d | 2,674,721 | 92.0 | d | 2,156,740 | 101.2 | d
CTC NCTC 2D/3D 6mm 5y^*^ | 3,489,238 | 81.3 | d | 2,706,113 | 87.2 | d | 2,172,677 | 98.0 | d

--- indicates default strategy (i.e., the least costly and least effective non-dominated strategy)

LYG = life-years gained vs. no screening; ICER = incremental cost-effectiveness ratio; d = dominated

* The two CTC strategies are not competing options; they represent a range of estimates of CTC test characteristics. They are shown here together for comparison purposes only. The ICERs are assessed separately using each CTC strategy in turn.

Figure 2 Discounted costs and discounted life-years gained per 1000 65-year-olds for 14 CRC screening strategies

Figure 2, Panel A Discounted costs and discounted life-years gained per 1000 65-year-olds for 14 CRC screening strategies* and the efficient frontier connecting the efficient strategies – MISCAN

* The two CTC strategies are not competing options; they represent a range of estimates of CTC test characteristics. They are shown here together for comparison purposes only. The ICERs are assessed separately using each CTC strategy in turn.

Figure 2A is a graph of the life-years gained per 1000 65-year olds compared to no screening compared to the total costs of screening per 1000 65-year-olds The data for these figures are in Table 9. The point of this figure is to assess what strategies provide the most life years gained for a given level of costs required to complete the screening strategies. Both life years and costs are discounted. The strategies considered are Hemoccult II (annually), Hemoccult SENSA (annually), fecal immunochemical test (annually), sigmoidoscopy with biopsy every 5 years, sigmoidoscopy without biopsy every 5 years, Hemoccult II plus sigmoidoscopy with biopsy, Hemoccult II plus sigmoidoscopy without biopsy, Hemoccult SENSA plus sigmoidoscopy with biopsy, Hemoccult SENSA plus sigmoidoscopy without biopsy, fecal immunochemical test plus sigmoidoscopy with biopsy, fecal immunochemical test plus sigmoidoscopy without biopsy, colonoscopy every 10 years, CT colonography with the Department of Defense (DoD) test characteristics, and CT colonography with the National CT Colonography Trial (NCTC) test characteristics. The strategies that provide the most life years gained for a given level of costs are called non-dominated strategies and represents the efficient frontier. For MISCAN the strategies on the efficient frontier are Hemoccult II, Hemoccult SENSA, Hemoccult II plus sigmoidoscopy with biopsy, Hemoccult SENSA plus sigmoidoscopy with biopsy, and fecal immunochemical test plus sigmoidoscopy without biopsy. With the exception of the sigmoidoscopy alone strategies (i.e., without an annual FOBT) and the CT colonography strategies, all other strategies are quite close to the efficient frontier. The CT colonography strategies (particularly with the test characteristics from the DoD study) are close to the colonoscopy strategy for life-years gained but the costs are significantly higher than the other strategies considered and are far from the efficient frontier.

Figure 2, Panel B Discounted costs and discounted life-years gained per 1000 65-year-olds for 14 CRC screening strategies* and the efficient frontier connecting the efficient strategies – SimCRC

* The two CTC strategies are not competing options; they represent a range of estimates of CTC test characteristics. They are shown here together for comparison purposes only. The ICERs are assessed separately using each CTC strategy in turn.

Figure 2B is a graph of the life-years gained per 1000 65-year olds compared to no screening compared to the total costs of screening per 1000 65-year-olds The data for these figures are in Table 9. The point of this figure is to assess what strategies provide the most life years gained for a given level of costs required to complete the screening strategies. Both life years and costs are discounted. The strategies considered are Hemoccult II (annually), Hemoccult SENSA (annually), fecal immunochemical test (annually), sigmoidoscopy with biopsy every 5 years, sigmoidoscopy without biopsy every 5 years, Hemoccult II plus sigmoidoscopy with biopsy, Hemoccult II plus sigmoidoscopy without biopsy, Hemoccult SENSA plus sigmoidoscopy with biopsy, Hemoccult SENSA plus sigmoidoscopy without biopsy, fecal immunochemical test plus sigmoidoscopy with biopsy, fecal immunochemical test plus sigmoidoscopy without biopsy, colonoscopy every 10 years, CT colonography with the Department of Defense (DoD) test characteristics, and CT colonography with the National CT Colonography Trial (NCTC) test characteristics. The strategies that provide the most life years gained for a given level of costs are called non-dominated strategies and represents the efficient frontier. For SimCRC the strategies on the efficient frontier are Hemoccult SENSA, Hemoccult II plus sigmoidoscopy without biopsy, Hemoccult SENSA plus sigmoidoscopy without biopsy, and colonoscopy. Strategies that are quite close to efficient frontier include Hemoccult II plus sigmoidoscopy with biopsy, Hemoccult SENSA plus sigmoidoscopy with biopsy, fecal immunochemical test plus sigmoidoscopy with biopsy, and fecal immunochemical test plus sigmoidoscopy without biopsy. The CTC strategies (particularly the strategy using the DoD test characteristics) are close to those of the colonoscopy strategy for life-years gained but the costs are significantly higher than the other strategies considered and are far from the efficient frontier.

Figure 2, Panel C Discounted costs and discounted life-years gained per 1000 65-year-olds for 14 CRC screening strategies* and the efficient frontier connecting the efficient strategies – CRC-SPIN

* The two CTC strategies are not competing options; they represent a range of estimates of CTC test characteristics. They are shown here together for comparison purposes only. The ICERs are assessed separately using each CTC strategy in turn.

Figure 2C is a graph of the life-years gained per 1000 65-year olds compared to no screening compared to the total costs of screening per 1000 65-year-olds The data for these figures are in Table 9. The point of this figure is to assess what strategies provide the most life years gained for a given level of costs required to complete the screening strategies. Both life years and costs are discounted. The strategies considered are Hemoccult II (annually), Hemoccult SENSA (annually), fecal immunochemical test (annually), sigmoidoscopy with biopsy every 5 years, sigmoidoscopy without biopsy every 5 years, Hemoccult II plus sigmoidoscopy with biopsy, Hemoccult II plus sigmoidoscopy without biopsy, Hemoccult SENSA plus sigmoidoscopy with biopsy, Hemoccult SENSA plus sigmoidoscopy without biopsy, fecal immunochemical test plus sigmoidoscopy with biopsy, fecal immunochemical test plus sigmoidoscopy without biopsy, colonoscopy every 10 years, CT colonography with the Department of Defense (DoD) test characteristics, and CT colonography with the National CT Colonography Trial (NCTC) test characteristics. The strategies that provide the most life years gained for a given level of costs are called non-dominated strategies and represents the efficient frontier. For CRC-SPIN the strategies on the efficient frontier are Hemoccult SENSA and colonoscopy. Strategies that are closest to the efficient frontier include Hemoccult II plus sigmoidoscopy without biopsy and Hemoccult SENSA plus sigmoidoscopy without biopsy. As with the MISCAN and SimCRC models, the CRC-SPIN model finds that the CT colonography strategies, and the strategy using the DoD parameters in particular, are close to the colonoscopy strategy in terms of the number of life-years gained but are considerably more costly than all of the other screening strategies and far from the efficient frontier.

Table 10 CT colonography unit cost thresholds (in 2007 US dollars) at which CT colonography strategies with a 6mm colonoscopy referral threshold are efficient screening options compared to other recommended CRC screening strategies. CT colonography strategies considered were base cases, sensitivity analysis with a 10-year interval and sensitivity analysis with different estimates of CT colonography test characteristics †

Simulation model | Base cases | | Sensitivity analysis, interval 10 years | | Sensitivity analysis, test characteristics †,*
Simulation model | CTC DoD 3D 6mm | CTC NCTC 2D/3D 6mm | CTC DoD 3D 6mm | CTC NCTC 2D/3D 6mm | CTC WC 2D/3D 6mm | CTC DoD 2D 6mm
MISCAN | 122 | 108 | 52 | 83 | 25 | 98
SimCRC | 199 | 183 | 266 | 241^‡^ | 83^‡^ | 163^‡^
CRC-SPIN | 196 | 205 | 352 | 371 | 173 | 246

† See Table 7 for the test characteristics used in these scenarios

* 5 yearly CT colonography screening interval

‡ CTC strategy is on the frontier as the least effective and least costly non-dominated strategy if the cost is at most this amount

Figure 3 CT colonography unit cost thresholds (in 2007 US dollars) at which CT colonography strategies with a 6mm colonoscopy referral threshold are efficient screening options compared to other recommended CRC screening strategies

CTC = computed tomography colonography; DoD = Department of Defense Study (30, 42); NCTC = National CT Colonography study (31); WC = hypothetical worst-case scenario

* CTC strategy is on the frontier as the least effective and least costly non-dominated strategy if the cost is at most this amount

Figure 3 has bar graphs depicting the unit cost thresholds (in 2007 US dollars) at which CT colonography strategies with a 6 mm colonoscopy referral threshold and a 5 yearly CT colonography are efficient screening options compared to other recommended CRC screening strategies. The costs are given for MISCAN, SimCRC and CRC-SPIN models. The costs are given for the DoD and NCTC base-cases and worst case (WC) and DoD 2D sensitivity analyses. The data plotted come from Table 10. For the DoD 3D base-case parameters the threshold cost is $122 for MISCAN, $199 for SimCRC, and $196 CRC-SPIN and for the NCTC base-case parameters the threshold cost is $108 for MISCAN, $183 for SimCRC, and $205 for CRC-SPIN. For the worst case sensitivity analysis parameters the threshold cost is $25 for MISCAN, $83 for SimCRC, and $173 for CRC-SPIN. For the DoD sensitivity analysis parameters with primary 2D reading, the threshold cost is $98 for MISCAN, $163 for SimCRC, and $246 for CRC-SPIN. All values are below the $488 base case considered for CTC.

Figure 4 CT colonography unit cost thresholds (in 2007 US dollars) at which CT colonography strategies with a 10mm colonoscopy referral threshold are efficient screening options compared to other recommended CRC screening strategies

CTC = computed tomography colonography; DoD = Department of Defense Study (30, 42); J = Johnson study (40); NCTC = National CT Colonography study (31); WC = hypothetical worst-case scenario

* CTC strategy is on the frontier as the least effective and least costly non-dominated strategy if the cost is at most this amount

Figure 4 has bar graphs depicting the unit cost thresholds (in 2007 US dollars) at which CT colonography strategies with a 10 mm colonoscopy referral threshold and a 5 yearly colonoscopy are efficient screening options compared to other recommended CRC screening strategies. The results are given for the MISCAN, SimCRC, and CRC-SPIN models. The strategies considered were two using primary 3D reads, two using a mix of 2D and 3D reads, and two using primary 2D reads). The data plotted come from Table 11. For the DoD 3D parameters the threshold cost is $98 for MISCAN, $192 for SimCRC, and $132 CRC-SPIN and for the Johnson 3D parameters the threshold cost is $71 for MISCAN, $153 for SimCRC, and $105 for CRC-SPIN. For the NCTC parameters the threshold cost is $49 for MISCAN, $135 for SimCRC, and $90 for CRC-SPIN and for the worst case parameters the threshold cost is $10 for MISCAN, $81 for SimCRC, and $43 for CRC-SPIN. Finally, for the primary 2D sensitivity analysis scenarios, the threshold cost for the DoD study parameters is $75 for MISCAN, $160 for SimCRC, and $105 for CRC-SPIN and the threshold for the Johnson study is $73 for MISCAN, $154 for SimCRC, and $105 for CRC-SPIN.

Table 11 CT colonography unit cost thresholds (in 2007 US dollars) at which CT colonography strategies with a 10mm colonoscopy referral threshold are efficient screening options compared to other recommended CRC screening strategies †

Simulation model | Sensitivity analysis scenarios with 10mm colonoscopy referral thresholds
Simulation model | Primary 3D reads | | 2D/3D reads | | Primary 2D reads
Simulation model | CTC DoD 3D 10mm | CTC J 3D 10mm | CTC NCTC 2D/3D 10mm | CTC WC 2D/3D 10mm | CTC DoD 2D 10mm | CTC J 2D 10mm
MISCAN | 98 | 71 | 49 | 10 | 75 | 73
SimCRC | 192^‡^ | 153^‡^ | 135^‡^ | 81^‡^ | 160^‡^ | 154^‡^
CRC-SPIN | 132^‡^ | 105^‡^ | 90^‡^ | 43^‡^, | 110^‡^ | 105^‡^

CTC = computed tomography colonography; DoD = Department of Defense Study (30, 42); J = Johnson study (40); NCTC = National CT Colonography study (31); WC = hypothetical worst-case scenario

† See Table 7 for the test characteristics used in these scenarios

‡ CTC strategy is on the frontier as the least effective and least costly non-dominated strategy if the cost is at most this amount

Table 12 CT colonography unit cost thresholds (in 2007 US dollars) at which CT colonography strategies with a 6mm colonoscopy referral threshold are efficient screening options compared to other recommended CRC screening strategies for different levels of adherence with CT colonography screening

Simulation model | Base case (CTC DoD 3D 6mm 5y) | Sensitivity Analysis on CTC Adherence^†^
Simulation model | Adherence 50% for all strategies | CTC adherence 55% | CTC adherence 62.5%
MISCAN | 122 | 293^‡^ | 547^‡^
SimCRC | 199 | 408^‡^ | 694^‡^
CRC-SPIN | 196 | 360^‡^ | 668^‡^

CTC = computed tomography colonography; DoD = Department of Defense Study (30, 42);

† Strategies other than CTC remain at 50% adherence

‡ CTC strategy is on the frontier with an incremental cost-effectiveness ratio (ICER) of $50,000 if the cost is at least this amount

Table 13 CT colonography unit cost thresholds (in 2007 US dollars) at which CT colonography strategies with a 6mm colonoscopy referral threshold are efficient screening options compared to other recommended CRC screening strategies for modified societal perspective

| Total threshold costs (includes co-payments and patient time costs) | | CMS payment rates (excludes co-payments and patient time costs)
Simulation model | CTC DoD 3D 6mm | CTC NCTC 2D/3D 6mm | CTC DoD 3D 6mm | CTC NCTC 2D/3D 6mm
MISCAN | 181 | 154 | 26 | NT
SimCRC | 332 | 324 | 177 | 169
CRC-SPIN | 318 | 336 | 163 | 181

CTC = computed tomography colonography; DoD = Department of Defense Study (30, 42); NCTC = National CT Colonography study (31)

Table 14 CT colonography unit cost thresholds (in 2007 US dollars) at which CT colonography strategies with a 6mm colonoscopy referral threshold are efficient screening options compared to other recommended CRC screening strategies for different levels of payment of anesthesia costs

| Base case (CTC DoD 3D 6mm 5y) | Sensitivity Analysis on anesthesia payment
Simulation model | No payment | 29% payment | 100% payment
MISCAN | 122 | 119 | 114
SimCRC | 199 | 199 | 198
CRC-SPIN | 196 | 204 | 221

CTC = computed tomography colonography; DoD = Department of Defense Study (30, 42)