# DISCUSSION

## Summary of Results

We used three independent microsimulation models to evaluate the cost-effectiveness analysis of CT colonography in comparison with the currently recommended CRC screening tests of colonoscopy, flexible sigmoidoscopy, and FOBT (guaiac Hemoccult II and SENSA, and immunochemical). The analysis is based on a cohort of previously unscreened 65-year-old individuals followed over their lifetimes and is conducted from both the CMS payer perspective and a modified societal perspective. We evaluated two recent large-scale CT colonography studies as our base case with referral to optical colonoscopy for a CT colonoscopy-detected lesion of 6 mm or larger diameter and with repeat screening with CT colonography every 5 years. Sensitivity analyses were conducted for referral of individuals with only larger lesions (10 mm or larger) and for longer repeat screening intervals (10 years) as well as for worse case test parameters. Even though the life-years gained by 5-yearly CT colonography with a 6 mm referral for optical colonoscopy were slightly lower than those from colonoscopy screening every 10 years, the overall costs of both base case CT colonography strategies were higher than all of the other screening strategies considered and were dominated. However if CT colonography payment costs were relatively lower than that of colonoscopy, or CT colonography adherence was differentially higher than for other CRC screening tests, including colonoscopy, then screening with CT colonography would be a cost-effective alternative. These findings are based on Medicare payment rather than on allowable charges which would be higher to account for patient copays.

At first it may seem surprising that CT colonography, based on the best evidence available to date, was not cost-effective when compared with the other CRC screening tests since the CT colonography sensitivity for the larger adenomas (10 mm or larger) and CRC is almost comparable to that of optical colonoscopy and the cost for CT colonography per scan was slightly less that of optical colonoscopy. However, the strategy of CT colonography screening is not a single test but a two-step procedure with those with 6 mm or larger polyps referred to optical colonoscopy. In addition, repeat screening is every 5 years rather than every 10 years as for colonoscopy. Thus for people who never had an abnormality detected, the costs of CT colonography accrues twice as often as the cost of optical colonoscopy. For those who have a positive finding on CT colonography, they accrue the cost of a diagnostic colonoscopy as well as the cost of the screening CT colonography. Consequently the aim of this analysis was also to explore the conditions under which CT colonography (or for that matter any other new test) could be considered cost-effective compared with the existing screening tests. We therefore conducted threshold analyses to determine what a CT colonography would have to cost in order for one of the CT colonography strategies to lie on the efficient frontier (i.e., be a non-dominated strategy). CT colonography screening could be cost-effective (i.e., be a non-dominated strategy) at a cost of $108 to $205 per scan depending on the simulation model used and the test characteristics of CT colonography. If the cost per test were $179 to $237, CT colonography would provide additional years of life at the same cost per year as colonoscopy (with CMS payment of approximately $500 for colonoscopy without polypectomy and $650 for colonoscopy with polypectomy).

We conducted sensitivity analyses to address the question of whether with increased adherence CT colonography would be on the efficient frontier. For this analysis we assumed that adherence was 50% for the currently-recommended tests and that there was increased adherence with the CT colonography test strategies among the unscreened individuals. If screening adherence were higher with CT colonography compared with other screening tests, CT colonography screening could be included among the efficient strategies at the base-case cost estimate of $488. However this is a hypothetical situation. To date we do not know of a clinical study that has demonstrated that the addition of CT colonography to the currently available screening tests will increase the overall population screening rates by increasing adherence in those previously unwilling to be screened.

We assumed that all in the cohort of 65-year-old individuals were previously unscreened. In reality, many subjects entering the Medicare program will have had CRC screening before age 65. Of those with prior screening, only those without adenomas detected are still eligible for average-risk screening. Adenoma patients should undergo more frequent surveillance with colonoscopy (20) than those with no neoplasia. This means that on average the eligible population for average-risk screening entering Medicare will be at lower risk than an unscreened population. Accordingly we may have overestimated the life-years gained from screening. However, this holds for all tests and strategies and is therefore not expected to significantly influence our results, because the relative performance of one test over the other remains the same. We assessed the potential effect of the assumption of an unscreened 65-year-old population by determining threshold costs for CT colonography screening when screening a 50-year-old cohort from age 50 onwards; the results did not change substantially. Furthermore, we investigated the impact that our assumption of a previously unscreened population would have, by estimating the threshold costs of CT colonography for a 65-year-old cohort at 50% lower risk for one of the models (MISCAN). We found that threshold costs for CT colonography did not change by more than $8. The direction and magnitude of the change depended on the base case strategy considered. Thus, we expect that the threshold cost would be similar for a population that has been previously screened compared to those of our baseline analysis using a previously unscreened population.

## Cost-effectiveness of Currently Recommended Test Strategies

As reported in the DNA stool test report to CMS, (25) an important finding from our analysis is that the currently recommended CRC screening tests provide good value for the resources spent. Hemoccult II, the test proven in randomized controlled trials to reduce CRC mortality by 15–33%, with a $4.54 CMS payment, is cost-saving relative to no screening but with the lowest life years gained with screening. Other FOBTs as well as flexible sigmoidoscopy and colonoscopy provided additional life-years gained over Hemoccult II, often with reasonable costs. Our favorable cost-effectiveness result for the CRC screening strategies is likely due to the increasing costs of CRC-related care and the costs of the screening tests not increasing at the same rate or even lower than previously reported. In this analysis all the costs come from the same source: Medicare payment. The costs for treating CRC stage III and IV and incurable CRC have been increasing since the introduction of newer therapies. The reason that the SimCRC and CRC-SPIN models found more cost-saving strategies than the MISCAN model is likely due to the fact that they find a greater reduction in cancer incidence with CRC screening because of their longer dwell times.

## Evaluation of New Screening Tests in Relationship to Current Recommendations

CRC screening guidelines from the Multi-Society Task Force were published in 1997(18) for currently available tests but the authors also considered how to evaluate new screening tests as well. The guidelines state that a newer test could be substituted for a currently recommended test (or added to the recommendations) if evidence were available to demonstrate that the new test had: (1) a comparable performance for sensitivity and specificity in detecting cancer or adenomatous polyps at comparable stages, (2) was equally acceptable to patients, and (3) had comparable or lower complication rates and costs (18). We address each of these issues below on the strength of the evidence as a screening test and include how the results from the microsimulation modeling are informative for these issues.

### Comparability of CT colonography sensitivity and specificity in detecting colorectal cancer and adenomas to other screening tests such as colonoscopy

The sensitivity of CT colonography varied for the two base cases with the Department of Defense study (30) having comparable sensitivity to detect adenomas 6 mm or larger and colorectal cancers as optical colonoscopy but with the larger community-based National CT Colonography trial (31) having lower sensitivity than that of optical colonoscopy. Adenomas of size <6 mm are not reported at all for CT colonography (86). The natural history of adenomas <6 mm is not well known (72, 87, 88). The risk of high-grade dysplasia or invasive CRC is lower in these smaller adenomas than those ≥6 mm but the smaller lesions are also the most common. Repeat CT colonography screening at 5-year intervals with referral to optical colonoscopy for those lesions of larger size is one way to offset the optical colonoscopy screening strategy of removing all polyps.

The specificity of CT colonography also varied for the two base cases, with the Department of Defense study (30) having lower specificity (80%) than the National CT Colonography trial (88%) (31). Lack of specificity is also a factor in optical colonoscopy which detects and removes hyperplastic and other polyps as well as the adenomas less than 6 mm in size. In the analyses we assumed 90% specificity for optical colonoscopy to take into account the detection and removal of non-adenomas in optical colonoscopy screening.

The clinical evidence to date has primarily been for a single point-in-time assessment of CT colonography. Information on programmatic use of CT colonography (i.e., repeated screening) is not yet available. Future studies are needed to assess repeat screenings and the impact of a programmatic adherence of CT colonography.

The evidence shows that there is a strong learning curve for CT colonography and that readers must have standardized rigorous training and proper technique to obtain the test characteristics that we used in our analyses, based on two well-designed trials. Quality measures for CT colonography are in development (28).

CT colonography has improved rapidly in the past decade. In Mulhall’s meta-analysis, primarily composed of the earlier studies, the sensitivity increased with a decrease in CT colonography slice thickness, use of multidector CT scanners, and concomitant 2D and 3D imaging (37). Additional improvements in CT colonography are to be expected. However new techniques or modifications of older techniques must be evaluated as to their test performance characteristics. An assessment of sensitivity and specificity with respect to specific improvements in CT technology was beyond the scope of this report.

Additional techniques are demonstrated for optical colonoscopy to detect flat adenomas (89) and the clinical importance of flat adenomas has been discussed (90). The CT colonography literature has also discussed detection of flat lesions (91, 92). In a retrospective review of the National Polyp Study O’Brien (93) noted that a large percent of small (<6 mm) sessile adenomas detected by colonoscopy without additional techniques would now be classified as flat lesions. However, flat depressed lesions would be likely to be missed by both optical colonoscopy and CT colonography. Additional techniques to detect flat adenomas have not been included in the modeling for this report.

We use three independently developed microsimulation models to project the life-years gained and the lifetime costs associated with CT colonography strategies compared with other currently recommended CRC screening strategies. CT colonography screening, with referral to colonoscopy of 6 mm lesions and with a 5-year screening interval, provides life-years gained slightly lower to that of optical colonoscopy repeated every 10 years and more comparable to that of a program of flexible sigmoidoscopy with FOBT. The life years gained are greater for the CT colonography base case from the Department of Defense than for that from the National CT Colonography Trial for all three microsimulation models.

### Acceptability to patients as a screening test

The currently-recommended CRC screening tests all require considerably more patient involvement than screening tests for other diseases. The individual undergoing screening must complete a cleansing bowel prep for colonoscopy, flexible sigmoidoscopy as well as for CT colonography, restrict their diet for Hemoccult II, colonoscopy, and CT colonography; and restrict NSAID use with Hemoccult II; have contact with the stool for any of the FOBTs; and go to a medical setting for colonoscopy, flexible sigmoidoscopy, or CT colonography. Colonoscopy procedures have a small but real risk of perforations and due to sedation, require an escort to and from the procedure. Although CT colonography is non-invasive it does require a cathartic bowel preparation just as for optical colonoscopy, as well as stool tagging. In addition, a positive CT colonography requires referral for optical colonoscopy as is the case for other two-step procedures. Whether same-day CT colonography and optical colonoscopy for those with a positive CT colonography is possible in the general medical practice is not yet known although there is discussion of this as a practice model (94). If not, then the referred patient must undergo two cathartic preparations. The patient impression is often that CT colonography is ‘virtual’ and non-invasive. It is not known whether the adherence to optical colonoscopy referral for those with positive CT colonography will be as high or higher as those with positive findings on other CRC screening tests. Although non-cathartic preparations have been developed for CT colonography (95, 96) they involve both dietary restriction over a number of days and ingestion of various oral contrast agent (97). Consequently, the non-cathartic preparations are not ‘prepless’. Also same-day optical colonoscopy cannot be performed in those with non-cathartic preparations if the CT colonography is positive for lesions of size 6 mm or larger.

There is a low level of radiation exposure with CT colonography. The long-terms effects of cumulative exposure to radiation that would be associated with interval screening with CT colonography are unknown (98, 99). In addition, concern for radiation risk on part of patient or physician could affect willingness to adhere to CT colonography screening.

Patient-stated preference for CT colonography relative to other CRC screening tests has been investigated in those who have had CT colonography. Pickhardt conducted a survey of patient preferences for repeat CT colonography versus repeat optical colonoscopy (30) and demonstrated a slight preference for CT colonography. Gluecker (100) addressed patient preferences for those having CT colonography and colonoscopy versus those with CT colonography and double contrast barium enema; CT colonography was preferred. Bosworth (101) reported that patients who completed optical colonoscopy, CT colonography, and barium enema preferred optical to virtual colonoscopy. Schwartz (102) reported that in a tertiary care center (University of Wisconsin) that the successful initiation of a screening CT colonography program did not result in a decrease in the number of total colonoscopy examinations or screening colonoscopies. These findings could suggest that those having CT colonography screening examinations might have been drawn from those who had not had prior CRC screening. However, prior screening history was not reported in that study. Also as a tertiary care referral center, it is difficult to determine screening rates in a population and whether the rate of no screening decreased. Further studies of patient preference (and adherence) for CT colonography versus optical colonoscopy for the initial screen and of the willingness to have optical colonoscopy if CT colonography is positive are needed, especially among subjects who have been unwilling to perform any of the current CRC screening tests (21).

The US Preventive Services Task Force suggested that CT colonography could be an important option in a colorectal cancer screening program if this test was accepted by subjects who would have otherwise refused other colorectal cancer screening options (17). Our analysis shows that CT colonography screening would need to change screening participation in approximately 10–20% of individuals who would otherwise remain unscreened in order for CT colonography to be cost-effective at a payment rate similar to that for colonoscopy without polypectomy. Further research on CRC screening adherence, including how such adherence is affected by the availability of CT colonography, and willingness to complete optical colonoscopy to evaluate a positive CT colonography test is needed. In our base case analyses we assumed 100% adherence for all phases of testing but we also recognize that in practice that follow up of positive tests is less than 100%.

### Evidence on comparable or lower complication rates and costs

There are perforation complications associated with CT colonography but at a lower rate and with less substantial level of complications as colonoscopic complications (38). There is radiation exposure with CT colonography but at a low level. The harm of low-level radiation has been difficult to assess. Furthermore followup of extracolonic findings detected on CT colonography does contribute to a higher cumulative dose of radiation exposure that should be taken into account (21, 98). Risk may be small, but certainly is not negligible.

## Cumulative radiation exposure

CT colonography is associated with exposure to radiation. Brenner (98) estimated that the excess cancer risk from a pair of CT colonography scans using typical current scanner techniques is about 0.14% for a 50-year old and half that for a 70-year old. This estimate is controversial, because it was based on simulation calibrated to atomic bomb survivors. Multiple CT colonography screens will increase the radiation dose proportionally and most likely also the radiation risks. We found in our microsimulation modeling analysis that CT colonography is only compatible to colonoscopy screening if offered seven times (every 5 years between ages 50 and 80), potentially leading to an excess cancer risk of approximately 0.47%. This will lead to life-years lost due to CT colonography which are not negligible compared to the life-years gained. We did not take these excess cancer cases into account. The US Preventive Services Task Force cited lack of knowledge as to whether the radiation exposures associated with CT colonography represented a net benefit or a net loss as to not currently recommend CT colonography for colorectal cancer screening in the average risk population (17, 38). There is good evidence that radiation dose with CT colonography can be reduced by at least a factor of 5 (and perhaps as much as 10), while still maintaining sensitivity and specificity for polyps larger than approximately 5 mm (103). Automatic exposure control options on the latest generation of scanners may facilitate reducing CT-related doses (99). The latest colorectal cancer screening guidelines from the American College of Radiology stress the appropriate use of low-dose protocols for CT colonography in screening (28). With these dose reductions, excess risk of cancer from CT colonography could be reduced.

## Extracolonic findings

Although CT colonography has been developed as a screening tool to detect colorectal adenomas and CRC, extracolonic lesions are also unavoidably visible (and therefore screened) on the CT colonography scans. There is considerable discussion as to whether the extracolonic findings with CT colonography represent an asset or liability (72, 104, 105). Some of the extracolonic findings include abdominal aortic aneurysms and extracolonic cancers. A one-time screening for abdominal aortic aneurysms is recommended by the USPSTF with ultrasonography only for men age 65 to 75 who have ever smoked (106). An evaluation of the harms and risks of detecting extracolonic lesions is beyond the scope of this report. In our base case analysis we did not include the costs of detecting and evaluating extracolonic findings because we could not also include the harms and benefits. However the implicit assumption that we are making by not formally incorporating these costs, harms and benefits into the analysis is that, conditional on a CT colonography examination being done, cost-effective approaches to follow-up care of extracolonic finding are being adopted. It is not clear at this time whether this is a valid assumption. As noted by Pickhardt an assessment of the overall cost effectiveness of extracolonic evaluation would require a detailed longitudinal analysis of the long term clinical outcomes and potential benefit derived from early detection of a wide variety of detectable extracolonic disease (72). Given that further studies are needed to answer this question, we have focused the discussion below on the prevalence of the extracolonic findings and the costs associated with evaluating these findings.

There is a wide range in definitions and classifications of extracolonic lesions, the procedures for reporting extracolonic lesions, and the recommendations for further work-up of such lesions. The overall rates of any extracolonic lesions have ranged from 27% (107) to 69% (108) in a screening population. The prevalence of clinically significant extracolonic findings is generally lower with a range from 4.5% in the Department of Defense study (30) to 16% in the National CT Colonography Trial (31). The definition of clinically significant findings has varied across studies but in general use meant a finding which should result in a referral for further evaluation. In several studies (107 –109) the cost for the extracolonic assessment is only those costs for additional radiological evaluation. These costs for additional radiological evaluation are averaged across all with CT colonography screening; average costs range from $24 to $34 per patient screened. These average costs reflect both the percent with clinically significant findings detected, as well as the percent of patients who received further radiological work-up of the total number screened. Additional costs due to surgical or medical evaluation and treatment, laboratory evaluations, and longer term medical surveillance for these conditions were not included. In 2008 Pickhardt (72) reported that the average surgical and inpatient hospital costs ($67.54) per patient screened by CT colonography were higher than the non-surgical ($31.02) costs of evaluating unknown extracolonic findings of at least moderate potential clinical importance in a prospectively screening CT cohort. (Further medical evaluation and surveillance was not included in these costs.) Clear guidance is needed in what findings should be considered as clinically important. Xiong (110) and Kimberly (111) reported the evaluation of extracolonic findings in cohorts in which all extracolonic findings were reported to the primary care physicians without guidance as to what findings required further evaluation. Average cost for evaluating the extracolonics was $248 per patient screened for the Kimberly cohort and £153 (in 2006) for Xiang’s cohort. Both studies included costs from clinic visits, imaging and laboratory studies, and medical procedures that were generated as a result of detection of extracolonic findings at CT colonography screening. In the Kimberly cohort 18% had clinically important extracolonic findings but 24% of patients screened had further evaluation. The average cost across all with CT colonography screening was $185 for additional radiographic imaging, $8 for laboratory studies, and $38 for medical procedures. In the Xiong cohort 52% had at least 1 extracolonic finding; 11% of all screened had further evaluation; 87% of the total costs for evaluation were generated by surgical treatments and their sequelae. (General Practice consultation fees were not included in the costs.) These results represent the wide variation in classification of extracolonic findings reported for evaluation, the range of costs ascertained by the different studies, and the time periods of evaluating subsequent medical management initiated from the initial notification of extracolonic findings.

Pickhardt (73) notes that there are clinical and ethical concerns in withholding or not reviewing imaged regions and advocates for responsible management of further evaluation of extracolonic findings. In 2005 the Working Group on Virtual Colonoscopy of the American College of Radiology Colon Cancer committee developed a quality assessment tool for CT colonography which includes a classification system for extracolonics with recommendations for further evaluation of those which could be clinically important (86). E0 findings are those from a limited exam; E1 a normal examination; E2 clinically unimportant finding; E3 likely unimportant finding, incompletely characterized, but work-up may be indicated and E4, potentially important finding; which should be communicated to the referring physician. Prior to this classification the definition of the extracolonic findings and the severity level of triggering referral for work up has varied. This system, if universally adopted, may help to ensure that referrals for evaluation of extracolonic lesions are done more consistently and appropriately.

The US Preventive Services Task Force found that thus far there is insufficient evidence to determine whether there is net benefit or net harm to evaluation of extracolonic findings and has stated this lack of evidence as a reason for not recommending CT colonography as a screening test for the average risk population (17). A thorough assessment of this issue will require long-term follow-up of a screening cohort with assessment of the prevalence, follow-up, treatment for extracolonic findings and any attenuate complications. Such a study will need to include all medical costs from radiology, surgery, laboratory, drugs, or other associated medical activities to evaluate and treat conditions uncovered as extracolonic findings. There is not sufficient evidence in this format in the literature. In this report we presented a summary of the prevalence of extracolonic findings in screening and in symptomatic cohorts and the costs incurred in evaluation. A fuller assessment is beyond the scope of this report.

## Consistency of Results from Three Microsimulation Models

All analyses were conducted by three separate microsimulation modeling groups of the National Cancer Institute-sponsored modeling consortium, CISNET, using independently developed models but with common inputs. The comparability of the findings of the three modeling groups strengthens the credibility of our results and can be viewed as a sensitivity analysis on the underlying natural history assumptions. The three models were independently developed prior to performing the cost effectiveness analyses presented here. All three models have been calibrated to CRC incidence rates from a pre-screening era. All the models have been extensively validated against clinical trial data on Hemoccult II screening. The models do differ in the dwell time from adenoma to clinically detectable CRC. The MISCAN model assumes a shorter dwell time compared with the SimCRC and CRC-SPIN models. Based on this difference in dwell time, the MISCAN model estimates fewer life-years saved from removing adenomas as a result of screening than the SimCRC and CRC-SPIN models, and estimates a greater benefit for shorter rescreening intervals for adenoma-sensitive tests than does the other two models. The fact that all three models come to similar conclusions with respect to cost-effectiveness and threshold costs of CT colonography screening shows the robustness of the results for uncertainties in the duration of the adenoma-carcinoma sequence.

The distribution of dwell time from adenoma to carcinoma is not known with certainty. The uncertainty on dwell time affects the assessment of all the screening tests, including CT colonography. In particular it affects the tests with respect to detection of adenomas.

The microsimulation models are well situated to address the comparison of CT colonography to other colorectal cancer screening strategies in relationship to differences in sensitivity by size of adenomas and of colorectal cancer, the impact of varying lesion size cut points for referral on to optical colonoscopy, varying the years before CT colonography rescreening and deferential differences in adherence. The microsimulation modeling results also reflect a program of systematic screening, surveillance, and treatment from ages 65 to 80 with follow-up until age 100 of all in the cohort. Thus programmatic effects are ascertained over time.

## Other Cost-effectiveness Analyses

Several other studies have been published on the cost-effectiveness of CT colonography screening in the general population (Table 15). In all these studies, the threshold costs for CT colonography screening were higher than the 25–40% of colonoscopy costs found in this study. An important reason for this is that we compared CT colonography screening with all other available test strategies, whereas most other studies compared CT colonography only to colonoscopy, sigmoidoscopy or Hemoccult II. None of the other cost-effective analyses included the improved Hemoccult SENSA or fecal immunochemical testing strategies as a comparator. Sonnenberg estimated that 10-yearly intensive CT colonography should cost 46% of colonoscopy costs to have the same costs per life-year gained (112). The estimated threshold costs from Ladabaum were slightly higher (60%), but he assumed better CT colonography test sensitivity (113). Comparing 10-yearly CT colonography with 10-yearly colonoscopy in our study yielded threshold costs of 49–71% of colonoscopy costs (Appendix 4), but we had a referral threshold of 6 mm instead of 0 mm. Vijan compared CT colonography every 5 years (referral of all lesions) with 10-yearly colonoscopy(114). They found threshold costs of 75% of colonoscopy costs. A similar comparison, but with a 6 mm threshold in our study, yields costs of 39–44% (Appendix 4). This is explained by better specificity in Vijan’s assumptions. Using the performance characteristics of 2D CT colonography (which had lower sensitivity than in this analysis, but still better specificity), Vijan found very low CT colonography threshold costs. Finally, Pickhardt compared 10-yearly CT colonography screening with a referral threshold of 6 mm to 10-yearly colonoscopy screening (42). He found that with CT colonography costs at 70% of colonoscopy costs, CT colonography screening with referral of lesions 6 mm and larger was cost-effective compared to colonoscopy. This is somewhat higher than the estimate from the same comparison in our study (49 –71%).

Recent cost-effectiveness analyses include Landsorp-Vogelaar (115) and the Canadian Agency for Drugs and Technologies in Health (116) with similar findings that CT colonography is dominated by optical colonoscopy.

Table 15 Literature overview of US studies estimating the cost-effectiveness of CT colonography screening in the average-risk population

Study | Comparator strategy | Sensitivity CTC for adenomas | Specificity CTC | Threshold costs as % of colonoscopy costs
Sonnenberg 1999 | 10-yearly colonoscopy | 80% | 95% | 46% for 10-yearly CTC, referral 0 mm
Ladabaum 2004 | 10-yearly colonoscopy | Small: 87% Medium: 87% Large: 94% | 85% | 60% for 10-yearly CTC, referral 0 mm
Vijan 2007 | 10-yearly colonoscopy | Small: 46% Medium: 83% Large: 91% | 91% | 75% for 5-yearly CTC, referral 0 mm
Pickhardt 2007 | 10-yearly colonoscopy | Small: 48% Medium: 70% Large: 85% | 86% | >70% for 10-yearly CTC, referral 6 mm

CTC: CT-colonography

## Limitations of Modeling Assumptions

The models simulate the progression from adenoma to CRC by increasing the size of the adenomas over time. Because adenoma size, villous component, and high-grade dysplasia are highly correlated (88), the size representation indirectly represents histology and high grade. However, the models do not separately simulate the step from adenoma with low-grade dysplasia to an adenoma with high-grade dysplasia. We also did not allow for de novo cancers (cancers that arise without a prior adenoma state). Lastly, we assumed that SEER incidence data prior to the time of active CRC screening in the US is a good representation of the cancer incidence expected today in an unscreened population. However, because there has been a small net improvement in CRC lifestyle risk factors for CRC over time (46, 61), estimates of CRC incidence may be overestimated. The impact of overestimating CRC incidence is that all CRC screening benefits are also overestimated, though we would not expect significant differences in the relative benefit across strategies.

In the current analysis, we assumed conditional independence of repeat screenings. Consequently we assumed that there were no systematic false-negative results for adenomas and cancers. This is likely a reasonable assumption for FOBT and fecal immunochemical testing because bleeding of a lesion is assumed to be a random event, so that if a test misses a lesion the first time, then it has approximately the same probability of catching a bleed on the next screen. This assumption may be less reasonable for optical endoscopy, as certain lesions may be more difficult to find (e.g., in a fold) but is a reasonable assumption for CT colonography which can detect lesions on folds (117).

In this analysis, we included the current recommendations for average-risk CRC screening as the comparator strategies. We did not consider alternative screening intervals for the currently recommended screening tests. We also made the assumptions that screening would stop at age 80 and that individuals would remain on a surveillance schedule for their lifetime, which may not be realistic assumptions for what occurs in practice.

We did not use quality adjusted life years gained because we did not have good measures on the effects of screening on quality of life particularly as quality relates to the anxiety of waiting.

In our sensitivity analysis of screening adherence we assumed that individuals would be either fully adherent with a screening strategy or never screened. This is an oversimplification of what occurs in practice, but is closer to reality than an assumption that individuals show up randomly to their scheduled screens. A study by Coups et al. (118) of data from the 2000 National Health Interview Survey found that those who were not adherent to colorectal cancer screening were less likely to have a regular source of care and less likely to have visited a general practitioner in the previous 12 months and had more risk factors for colorectal cancer than those who were adherent.

## Limitations of Cost Estimates

The costs of the screening tests, as well as the costs of complications associated with screening (primarily colonoscopy), were based on 2007 Medicare payment rates. To the extent that these rates change differentially in the future (e.g., a decrease in the payment rate for colonoscopy) our results will change.

Costs for CRC treatment were for the period 1998 to 2003. In this period use of the expensive biological therapies cetuximab and bevacizumab was limited (119). We would expect that inclusion of these costs as later data become available would make the cost-effectiveness more favorable overall. CRC screening can have two potentially beneficial effects: 1) primary prevention of CRC through detection and removal of adenomas that might have eventually become cancer, and 2) early detection of CRC, when it is in an earlier stage that is more amenable to treatment. In general, those strategies that are associated with a higher reduction in cancer incidence (i.e., act largely through primary prevention rather than early detection) will have a greater net savings.

With the exception of Warren, Klabunde, and Brown upcoming manuscript (78), there are few data specifically on colonoscopy complications in the Medicare population. For example, the Warren analysis reports hospitalization for dehydration following colonoscopy. This complication was not cited in the general population studies across ages. Complications rates are generally lower in organized screening programs, which often focus on the age group of 50 to 65 for CRC screening. Consequently a program to track complications in Medicare beneficiaries who receive CRC screening would be of value to assess the magnitude of risk for this age group.