# COST-EFFECTIVENESS ANALYSIS

## Overview

We used three existing microsimulation models validated against the best available data (43 –46) to assess the effectiveness and cost-effectiveness of CT colonography, in comparison with the currently-recommended CRC screening strategies. Although randomized controlled trials are the preferred method for establishing effectiveness of (screening) interventions, they are expensive and require long follow-up. Accordingly, well-validated microsimulation models may be used to estimate the required resources and expected benefits from different screening policies and inform decision making. The validity of the models is based on clinical incidence data before the introduction of screening (1975–1979 Surveillance, Epidemiology, and End Results [SEER] data) and the size distribution of adenomas in colonoscopy and autopsy studies (47 –57). The external validity has further been tested on the results of large (randomized) screening and surveillance studies, such as the Minnesota Colon Cancer Control Study (4), the CoCap sigmoidoscopy study (58), and the National Polyp Study (9, 44).The models also use the same all-cause mortality estimates from the US life tables and colorectal cancer survival data from SEER (59). Finally, the models were able to explain observed incidence and mortality trends in the US when accounting for risk factor trends, screening practice and chemotherapy treatment (46, 60, 61). Using three models (i.e., a comparative modeling approach) adds credibility to the modeling results and serves as a sensitivity analysis on the underlying structural assumptions of the models, particularly pertaining to the natural history of colorectal disease. Through the CISNET consortium, standardized profiles of the each model’s structure and underlying model parameters and assumptions are available at http://cisnet.cancer.gov/profiles/.

We used the MISCAN, SimCRC, and CRC-SPIN simulation models to calculate the lifetime costs (discounted and undiscounted) and life expectancy (discounted and undiscounted) for a cohort of 65-year-old individuals residing in the US (i.e., eligible for Medicare benefits) under 14 strategies plus no screening. The 14 CRC screening strategies vary by screening test or combination of tests and screening interval. We conducted an incremental cost-effectiveness analysis from the perspective of CMS and discounted future costs and life years 3% annually (62).In this report, simple dominance means that a strategy was more costly and less effective than another strategy, and weak dominance refers to a strategy that is more costly and less effective than a combination of other strategies. Any screening strategy that demonstrated simple or weak dominance was not considered in cost-effectiveness calculations. The relative performance of the remaining strategies was measured using the incremental cost-effectiveness ratio, defined as the additional cost of a specific strategy, divided by its additional clinical benefit, compared with the next least expensive strategy. All non-dominated (efficient) strategies define the efficient frontier and may be cost-effective depending on the willingness to pay for a life-year gained. An incremental analysis, as described, is recommended by the Panel on Cost-Effectiveness in Health and Medicine (62) for competing strategies and will show whether the net benefits of CT colonography are a good value for the resources required compared with the currently available CRC screening strategies. We also conduct analyses of CT colonography compared with no screening, which shows whether the net benefits of CT colonography are a good value for the resources required among individuals who would not be screened at all without the availability of CT colonography.

## Microsimulation Modeling

The MISCAN, SimCRC, and CRC-SPIN models simulate the life histories of a population of at least 10 million individuals from birth to death. Each model has a natural history component that tracks the progression of underlying disease in the absence of screening. The models share many characteristics; they use similar model inputs and are calibrated to the same data regarding adenoma prevalence, cancer incidence, and stage distribution. These data were collected and processed as part of CISNET and can be considered the best-available data for informing the simulation models. As each simulated individual ages, there is a chance that an adenomatous polyp – a benign precursor lesion that may lead to CRC – develops. One or more adenomas can occur in any individual and each can develop into preclinical CRC (Figure 1). The risk of developing an adenoma depends on age, sex, genetic and other propensity factors. The models track the location in the colon and the size of each adenoma, which influence disease progression and the chance of being found by screening.

Adenomas can grow in size over time. Some adenomas eventually become malignant, transforming to stage I preclinical cancer. A preclinical cancer (i.e., not detected) has a chance of progressing through the stages (from stages I to IV) and may be detected by symptoms at any stage. We assume that adenomas are asymptomatic and can only be detected by a screening test.

Figure 1 Graphical representation of natural history of colorectal cancer as modeled by MISCAN, SimCRC, and CRC-SPIN models. The opportunity to intervene in the natural history through screening (adenoma detection and removal, and early detection) is noted by the dotted lines. Screening can either remove a precancerous lesion (i.e., adenoma), thus moving a person to the “No lesion” state, or through early detection, which makes an undiagnosed cancer clinically detected at a potentially earlier stage of disease where it is more amenable to treatment

Figure 1 is a simplified diagram of how the microsimulation models represent the adenoma-carcinoma sequence. Initially a person has no colorectal lesions but may develop one or more adenomas, each of which has the potential to grow. Some adenomas may progress to preclinical cancer and some of these may become a clinical cancer. Some individuals will die from their colorectal cancer. Others will die from other causes. Screening for colorectal cancer can affect the progression of disease. If adenomas are detected through screening and removed then that adenoma will not develop into a cancer. If screening detects a preclinical cancer then it may be diagnosed at an earlier stage when prognosis is better, thereby potentially preventing a colorectal cancer death.

To project the effectiveness of a screening strategy, the models incorporate a screening component together with the natural history model. The effectiveness of each screening test is modeled through each test’s ability to detect lesions (i.e., adenomas, preclinical cancer). Once screening is introduced, a simulated person who has an underlying adenoma or preclinical cancer has a chance of having it detected during a screening year depending on the sensitivity of the test for that lesion. For screened persons without an underlying lesion we apply the false-positive rate (1 – specificity) to determine whether or not that person will undergo an unnecessary follow-up examination. Hyperplastic polyps are not modeled explicitly but are reflected in the specificity of the test. In addition, a percentage of individuals with false-negative test results (i.e., adenoma or preclinical cancer present but not detected) will be referred to colonoscopy because of the detection of a hyperplastic polyp. Flexible sigmoidoscopy can only detect lesions located in the distal colon or rectum, while other tests have the ability to detect lesions in any part of the colorectal tract. Colonoscopy and to a lesser extent, CT colonography, are associated with a small mortality risk due to the risk of perforation during the procedure.

The models include the possibility of multiple adenomas or preclinical cancers. We assume that if a person has multiple lesions, if any of the lesions are detected by CT colonography, then the person is referred for evaluation with colonoscopy and polypectomy if necessary. An individual with multiple adenomas, especially multiple adenomas of a larger size, would be more likely on average to be detected by screening than an individual with a single small adenoma. All polyps that are detected by colonoscopy are removed via polypectomy.

A description of the model structure and assumptions for each model is given in Appendix 1. Furthermore the three models are compared with respect to the natural history outcomes for adenomas and colorectal cancer for individuals at age 65 in Appendix 2. A detailed description of the underlying parameters of the natural history for each model is given as a model profiler at http://cisnet.cancer.gov/profiles/to provide transparency of the models.

### Key differences in model structures

All three microsimulation models were independently developed and subjected to rigorous comparative evaluations prior to this cost effectiveness of CT colonography. Although the models are calibrated to the same data on adenoma prevalence and cancer incidence, the underlying distributions of dwell times (i.e., the total time spent with adenoma and preclinical cancer prior to symptom detection) differ among the three models. A key assumption in the MISCAN model is that there are two types of adenomas: progressive adenomas (adenomas that eventually can become cancer) and non-progressive adenomas (adenomas that cannot become cancer). In the SimCRC and CRC-SPIN models all adenomas have the ability to progress to cancer (although most will not during the lifespan of the individual). An additional difference is that CRC-SPIN models continuous size rather than discrete stages of adenoma size. Although all three models predict similar estimates of adenoma prevalence and CRC incidence, the difference in the adenoma growth assumptions results in different dwell time estimates among the models. In the MISCAN model adenomas and preclinical cancer have been present for 10 years on average before clinical diagnosis, while the estimate is approximately 22 years for SimCRC and 25 years for CRC-SPIN. Little is known about how fast this progression truly occurs. It is estimated that 30% to 50% of the population have one or more adenomas, but it is difficult to measure dwell time in a real population because, by definition, it is the period during which the condition is undiagnosed. As a result of the difference in dwell time, more life-years are gained from screening in the SimCRC and CRC-SPIN models than in the MISCAN model. In the MISCAN model the additional benefit of increasing screening frequency will be greater than that in SimCRC and CRC-SPIN. A summary of each model is in Appendix 1 and a more detailed summary is provided for each model at http://cisnet.cancer.gov/profiles/including parameters relating to the underlying natural history of colon adenomas and colorectal cancer such as transition probabilities and dwell times.

Another key difference among the models is the distribution of adenomas in the colorectal tract (see Appendix 2). In the MISCAN model, adenomas are assumed to have the same distribution as CRCs, while the SimCRC and CRC-SPIN models are calibrated to the distribution of adenomas from autopsy studies. Approximately 30% of CRCs are located in the rectum, while data from autopsy studies suggest that 8–10% of adenomas are located in the rectum. As a result of this difference, the MISCAN model finds strategies involving sigmoidoscopy to be more effective than the SimCRC and CRC-SPIN models, because a larger proportion of adenomas are within the reach of the sigmoidoscope.

## Study Population

We used the natural history models to estimate the distribution of underlying disease for the 65-year-old US population in 2005 in terms of the presence, location, size, and type (adenoma vs. preclinical cancer) of lesions. (See Appendix 2 for a comparison of the natural history models for age 65). We conducted an analysis of the effect of different screening strategies among a 65-year-old cohort of individuals who have never been screened as our base case.

In reality, many subjects entering the Medicare program will have had CRC screening before age 65. Of those with prior screening, only those without adenomas detected are still eligible for average-risk screening. Adenoma patients should undergo more frequent surveillance with colonoscopy (20) than those with no neoplasia. This means that on average the eligible population for average-risk screening entering Medicare will be at lower risk than an unscreened population. To explore the effect of our using an unscreened population at age 65, we conduct a sensitivity analysis for a 50-year-old cohort.

## Comparison Screening Strategies (Table 1)

In consultation with AHRQ and CMS, we compared CT colonography screening to the basic strategies of screening with FOBT every year, flexible sigmoidoscopy every five years, combinations of FOBT and sigmoidoscopy, and colonoscopy every 10 years (as stated in Section 410.37 of the Federal Register), which are recommended by the USPSTF (17); the American Cancer Society (21, 22), and/or the Multi-Society Task Force (18 –21). No screening was also considered. Although double contrast barium enema was included in the older screening recommendations for the USPSTF (15); it was not included in the newer USPSTF recommendations and is not considered in this analysis. Also the stool DNA test, which was evaluated by the CISNET modelers in a cost-effectiveness analysis in 2007 (25) was not included in this cost-effectiveness analysis for CT colonography. We evaluated three FOBTs: Hemoccult II, Hemoccult SENSA and immunochemical FOBT and two strategies for sigmoidoscopy (with and without biopsy). We used the same strategies considered by the CISNET modelers for the Technology Assessment for stool DNA (25).

Table 1 Non-CT colonography strategies evaluated in the cost-effectiveness analysis

Strategy | Abbreviation | Interval, test 1 (y) | Interval, test 2 (y) | Biopsy @ SIG?
No screening | -- | -- | -- | --
Hemoccult II | HII | 1 | -- | --
Hemoccult SENSA | HS | 1 | -- | --
Fecal immunochemical test | FIT | 1 | -- | --
Flexible sigmoidoscopy with biopsy | SIGB | 5 | -- | yes
Flexible sigmoidoscopy | SIG | 5 | -- | no
Hemoccult II, SIG | HII + SIGB | 1 | 5 | yes
Hemoccult II, SIG | HII + SIG | 1 | 5 | no
Hemoccult SENSA, SIGB | HS + SIGB | 1 | 5 | yes
Hemoccult SENSA, SIG | HS + SIG | 1 | 5 | no
Fecal immunochemical test, SIG | FIT + SIGB | 1 | 5 | yes
Fecal immunochemical test, SIG | FIT + SIG | 1 | 5 | no
Colonoscopy | COL | 10 | -- | --

-- indicates not applicable

## CT Colonography Strategies (Table 2)

We compared these screening strategies to CT colonography screening based on the test parameters of the Department of Defense study (30) using 3D imaging as the primary read and the National CT Colonography trial (31) using both 2D and 3D reads. Subjects with lesions 6 mm or larger detected by CT colonography were referred to colonoscopy. Those with no 6 mm or larger polyps detected had a repeat CT colonography in 5 years. The request for the National Coverage Analysis did not specify a repeat screening interval; we used a 5-year to rescreen (21).

In addition to these two base-case scenarios for CT colonography, we conducted a sensitivity analysis in which we explored CT colonography scenarios using primary 2D reads, referral of individuals with 10 mm or larger lesions for colonoscopy, and a 10-year interval for repeat screening (Table 2). We also considered a hypothetical worst-case strategy for CT colonography that had slightly lower test characteristics than all other CT colonography strategies evaluated, selecting either the value reported by Rockey et al (36) or a value lower than any of the two primary studies (including 2D primary reads), whichever was lower.

For the purposes of this report, we assumed that all individuals begin CRC screening at age 65 (i.e., the age at which Medicare eligibility begins in the general population) and end at age 80. Those with adenomas or colorectal cancer detected are assumed to have colonoscopic surveillance according to the Multi-Society guidelines (20, 21) and continue surveillance with no stopping age. The cohort was followed for their lifetimes to a maximum of age 100. The USPSTF has now recommended a stop age for CRC screening of age 75 (17, 23). We used the stopping age of 80 in this report to be consistent with the DNA stool report. We would expect similar ranking of strategies for stop age of 75 as well as 80 given comparable adherence.

Table 2 CT colonography strategies evaluated in the cost-effectiveness analysis

CT colonography strategy abbreviation | Study | Primary read | Colonoscopy referral threshold (mm) | Screening interval (y)
Strategies evaluated in the base-case analysis
CTC DoD 3D 6mm 5y | DoD | 3D | 6 | 5
CTC NCTC 2D/3D 6mm 5y | NCTC | 2D/3D | 6 | 5
Strategies evaluated in sensitivity analyses
CTC DoD 3D 6mm 10y | DoD | 3D | 6 | 10
CTC DoD 3D 10mm 5y | DoD | 3D | 10 | 5
CTC DoD 2D 6mm 5y | DoD | 2D | 6 | 5
CTC DoD 2D 10mm 5y | DoD | 2D | 10 | 5
CTC NCTC 2D/3D 6mm 10y | NCTC | 2D/3D | 6 | 10
CTC NCTC 2D/3D 10mm 5y | NCTC | 2D/3D | 10 | 5
CTC J 3D 10mm 5y | J | 3D | 10 | 5
CTC J 2D 10mm 5y | J | 2D | 10 | 5
CTC WC 2D/3D 6mm 5y | WC | 2D/3D | 6 | 5
CTC WC 2D/3D 10mm 5y | WC | 2D/3D | 10 | 5

CTC = computed tomography colonography; DoD = Department of Defense study (30, 42); NCTC = National CT Colonography Trial (31); J = Johnson study (40); WC = hypothetical worst case scenario

Estimates for sensitivity and specificity for these CT colonography strategies are given in Table 7.

### Follow-up, surveillance, and adherence

We relied on current recommendations for follow-up and surveillance assumptions and did not specifically evaluate different assumptions for follow-up or surveillance and thus cannot conclude anything about the most cost-effective follow-up approaches (18 –20). We assumed that any individual with a positive FOBT or a positive CT colonography (defined as the visualization of a lesion of size ≥6 mm) is referred for a follow-up colonoscopy. We evaluated two scenarios for flexible sigmoidoscopy: 1) all detected polyps are biopsied and any person with an adenomatous polyp is referred for a follow-up colonoscopy, and 2) all persons with detected polyps are directly referred for colonoscopy (i.e., no biopsy is performed). For the year in which both FOBT and flexible sigmoidoscopy are due, the FOBT is performed first and if positive, the subject is referred for colonoscopy. Flexible sigmoidoscopy is done only for those with a negative FOBT. If a follow-up colonoscopy is negative, then the subject is assumed to undergo subsequent screening with colonoscopy with a 10-year interval (as long as the repeat colonoscopy is negative) and does not return to the initial screening schedule, as is the recommendation of the US Multi-Society Task Force (20) and American Cancer Society (21). In other words, once a person has a colonoscopy, the individual remains on a colonoscopy schedule.

If adenomas are detected on colonoscopy then the individual begins surveillance with colonoscopy per the 2006 guidelines from the joint publication of the US Multi-Society Task Force and the American Cancer Society (20, 21). Individuals found with one or two adenomas that are both less than 10 mm in size will undergo colonoscopy surveillance every 5–10 years (5 years was used for the modeling; a longer interval is also recommended as noted). Individuals with at least one adenoma greater than or equal to 10 mm in size or with 3 or more adenomas will undergo colonoscopy surveillance every 3 years unless the surveillance colonoscopy is normal or only detects one or two adenomas of size <10 mm, then the next surveillance colonoscopy would be at 5 years.

For the base-case analysis we assumed that all individuals are 100% adherent with screening, follow-up, and surveillance procedures. In sensitivity analysis we examined less than optimal adherence to determine if differences in adherence affect our results see section on sensitivity analyses) We specified a stop age of 80 for screening but allowed all individuals with an adenoma detected to continue to have surveillance colonoscopies until a diagnosis of CRC or death from other causes. All simulated individuals were followed until death (or age 100). The life-years gained per scenario were derived relative to no screening.

## CRC Screening Test Characteristics

Table 3 contains an overview of test characteristics used in our analyses. For all strategies other than CT colonography, test characteristics were taken from those derived for our previous report on stool DNA screening (25). Test parameters are given by person for the FOBTs and by lesion for CT colonography, colonoscopy, and flexible sigmoidoscopy. The sensitivities stated in Table 3 are based on sensitivities of the test at one point in time. In evaluating a strategy for a program of repeat testing, we assumed conditional independence for all screening tests. In other words, the sensitivity for detecting an adenoma or cancer depended only on the disease status at the time of the screen and did not depend on the test results from previous screening tests. We assume that the test performance characteristics for FOBTs and CT colonography are based on assessment of the whole colorectum. For sigmoidoscopy and colonoscopy, the test characteristics apply to the portion of the colon and rectum reached by the scope.

## CT Colonography Screening Test Characteristics

The test characteristics for CT colonography are based on the literature review described above. As CT technology has changed rapidly, we used the sensitivity and specificity estimates from the two recent large-scale CT colonography screening trials (30, 31)for our base-case estimates. We did not combine the estimates from these two studies because of procedural differences in performing the tests such as segmental unblinding and types of bowel preparation that made the studies less comparable. Also the two studies differed in their estimates of adenoma (6 –9mm) sensitivity and specificity (30, 31). Other estimates were evaluated in sensitivity analyses (see section on sensitivity analyses below).

Estimates of sensitivity for adenomas 6–9 mm were not directly available from the published tables but could be derived mathematically. The estimate of sensitivity for adenomas of size 6–9 mm was derived from the Department of Defense and National CT Colonography published tables (30, 31) which provided sensitivity per adenoma by adenoma size of ≥6, ≥7, >8, ≥9 and ≥10mm. The number of adenomas detected by CT colonography for size 10 mm or larger was subtracted from the number of adenomas detected by CT colonography for size 6 mm or larger for the numerator for CT colonography sensitivity for adenomas of size 6–9mm. The number of adenomas detected by optical colonoscopy for size 10 mm or larger was subtracted from the number of adenomas detected by optical colonoscopy for size 10 mm or larger for the denominator for CT colonography sensitivity for adenomas of size 6–9mm. For the Department of Defense study (30) from the published Table 3 the sensitivity for 6–9 mm adenomas was (180-47)/(210-51) =0.836 and for the National CT Colonography study from the published Table 4 was (189-108)/(270-128) = 0.57.

Although we use adenoma specific inputs for CT colonography sensitivity by adenoma size, the outcomes of the model results are based on a per subject classification. For example, if the simulated subject has two adenomas, this patient has two opportunities for an adenoma to be detected and to be referred on for follow-up colonoscopy. The per-patient sensitivity resulting from the models is therefore higher than the per-adenoma sensitivity used as inputs for the models. We have compared the resulting per-patient sensitivity from the models using the Department of Defense and National CT Colonography per-adenoma sensitivities with the reported patient sensitivities and found that the modeled and observed per patient sensitivities compared well.

## CRC Screening Test Characteristics for non-CT colonography

### Fecal immunochemical test

There are multiple fecal immunochemical tests with varying cut points for positivity, number of slides, number of days tested, and preparations reported in the literature. In the 2003 report by van Ballegooijen (24) we reviewed the literature for fecal immunochemical tests, including HemeSelect, Monhaem, Flexsure, Magstream 1000 Hem SP, and Insure. The 2003 report was primarily based on the performance of the Insure test. We updated the estimates for fecal immunochemical testing based on a large study on sensitivity and specificity of the Magstream 1000/ Hem SP fecal immunochemical test (63). The results of the Morikawa study for CRC were 66% sensitivity for CRC and 95% specificity for CRC which were similar to the estimates of sensitivity of 70% and specificity of 95% used in the previous report on fecal immunochemical testing to AHRQ and CMS (24). Consequently we retained the estimates of the test’s specificity and sensitivity for cancer from the previous report. However detection rates for adenomas were slightly higher than in the 2003 report. Because the sensitivity estimates for adenomas in the 2003 report were based on limited data, we used the adenoma sensitivity estimates reported by Morikawa (63, 64) for the DNA stool report. A study by Allison (65) for a FlexSure OBT (currently marketed as Hemoccult ICT by Beckman Coulter) had sensitivity for CRC of 82% and for advanced adenomas was 29.5%. Specificity for the fecal immunochemical test was 98%. The test characteristics used in this analysis are within the confidence intervals of this study.

### Hemoccult SENSA

We assumed that the sensitivities of Hemoccult SENSA for adenomas and CRC were similar to those of fecal immunochemical test. However specificity was assumed to be lower for Hemoccult SENSA (24). In addition to yielding more false-positive results, the lower specificity of Hemoccult SENSA results in a greater number of chance findings of adenomas; consequently adenoma detection with SENSA was considered to be slightly higher than with a fecal immunochemical test. In the 2007 study by Allison (65), the sensitivity of Hemoccult SENSA for CRC was 64% (lower than for the fecal immunochemical test comparator) and for advanced adenomas was 41% (higher than for the fecal immunochemical test comparison). Specificity was 98% similar as that for the fecal immunochemical test comparator. Our sensitivity estimates for Hemoccult SENSA are within the confidence intervals of this study. The specificity is significantly higher than assumed in our analysis, but this high specificity is not corroborated by other studies.

### Hemoccult II

The estimated CRC sensitivity of Hemoccult II was not changed from the 40% estimated in the 2003 report (24) which was based on a synthesis of the randomized controlled trials (4, 6, 7). This sensitivity is considerably higher than the 13% found by Imperiale (66), but more in line with the 33% that Ahlquist (67) found. One of the reasons for this may be that in the Imperiale study (66) Hemoccult II was not centrally processed. The 40% sensitivity figure is consistent with the randomized trial results according to earlier modeling studies (7, 68) and other Hemoccult II studies (25). Sensitivities of Hemoccult II for adenomas were estimated by assuming the same ratio between adenoma sensitivity and CRC sensitivity as for a fecal immunochemical test.

### Flexible sigmoidoscopy

We assumed the same sensitivity for flexible sigmoidoscopy as for colonoscopy within the reach of the scope. The reach of the flexible sigmoidoscopy is generally measured and reported in terms of centimeters of reach rather than location in the colon. However, the models represent adenomas and CRCs by location. We used the correspondence of location and centimeters from the anus from autopsy studies (69) as well as the clinical study of Adam (70) that used an electromagnetic imaging device to record the 3-dimensional position of the scope to estimate the reach for flexible sigmoidoscopy. In a Kaiser Permanente study, 60 cm or more of the colorectum was visualized in 63% of sigmoidoscopies, and at least 40 cm of the colorectum was reached in 83% of sigmoidoscopies (58). We assumed that 80% of sigmoidoscopy examinations reach the junction of the sigmoid and descending colon and 40% reach the beginning of the splenic flexure. For the strategies of flexible sigmoidoscopy every 5 years with an annual fecal occult blood test, we used the test sensitivities for the individual tests.

### Colonoscopy

Sensitivity estimates for colonoscopy were based on a recent meta-analysis (71). In screening studies the reach of the colonoscopy has been high with over 90% reaching the cecum. We initially assumed a cecal intubation rate with colonoscopy of 95% in a screening setting. However, guidelines (19) recommend that incomplete colonoscopies are repeated. The 5% incomplete colonoscopies are therefore assumed to be repeated in the models, yielding a total reach of 98% over both colonoscopies. (Note that we did not assume that any of the CT colonography exams would be incomplete, which biases are analysis in favor of CT colonography screening.) We assume that all polyps detected at colonoscopy are removed.

Table 3 Test characteristics used in base-case analysis

Test | Sensitivity^*^ by adenoma size or CRC (%) | | | | Specificity (%)
Test | ≤5 mm | 6–9 mm | ≥10 mm | CRC | Specificity (%)
CTC DoD 3D 6mm | -- | 83.6^**^ | 92.2 | 92.2+ | 79.6^§^
CTC NCTC 2D/3D 6mm | -- | 57.0^**^ | 84.0 | 84.0+ | 88.0^§^
Hemoccult II | 2.0 | 5.0 | 12.0 | 40.0 | 98.0
Hemoccult SENSA | 7.5 | 12.4 | 23.9 | 70.0 | 92.5
Fecal immunochemical test | 5.0 | 10.1 | 22.0 | 70.0 | 95.0
Sigmoidoscopy^†^ | 75.0 | 85.0 | 95.0 | 95.0 | 92.0^‡^
Colonoscopy | 75.0 | 85.0 | 95.0 | 95.0 | 90.0^‡^

CTC = computed tomography colonography; DoD = Department of Defense study (30, 42); NCTC = National CT Colonography Trial (31); -- indicates sensitivity is not provided because size is smaller than the colonoscopy referral threshold of 6mm

* Sensitivity is provided per individual for stool-based tests and per lesion for endoscopy and CT colonography tests.

** Sensitivity for CT colonography for adenomas 6-9 mm was mathematically derived from published tables as

+ Sensitivity for CRC was assumed to be the same as for adenomas of size ≥10 mm due to the small number of colorectal cancers detected in the DoD and NCTC studies

§ The lack of specificity with CT colonography reflects the detection of non-adenomatous polyps, artifacts, and adenomas smaller than the colonoscopy referral threshold of 6mm.

† Test characteristics for sigmoidoscopy apply only to lesions in the distal colon and rectum.

‡ The lack of specificity with sigmoidoscopy and colonoscopy reflects the detection of non-adenomatous lesions. With sigmoidoscopy, the presence of non-adenomatous lesions induces biopsy costs (in the case of sigmoidoscopy with biopsy) or results in referral for colonoscopy (in the case of sigmoidoscopy without biopsy). With colonoscopy, non-adenomatous lesions are removed and therefore induce polypectomy and biopsy costs.

## Costs

### Payer’s perspective

The base-case cost-effectiveness analysis was from the payer’s (CMS) perspective with costs stated as those which Medicare pays. These payments reflect approximately 80% of the allowable charge, including the facility charges (as applicable) and physician services charges. The beneficiary’s co-pay is not reflected in the analysis.

We also conducted an analysis from a modified societal perspective by including direct costs borne by beneficiaries as well as estimated patient time costs, but excluding costs due to lost productivity caused by early death or disability.

Screening costs were based on information provided by CMS on Medicare payments in 2007 for procedures and tests associated with CRC screening and complications of screening as reported in the DNA stool test cost –effectiveness analysis (Appendix 4 of that report (25) and replicated here in Appendix 6). Net costs of CRC-related care were obtained from an analysis of SEER-Medicare linked data. We did not include the cost of a separate office visit for any of the screening strategies as we assumed that all recommendations or arrangements for screening would already be associated with a previously-scheduled office visit.

The screening test costs are provided in Table 4. The costs for FOBT, flexible sigmoidoscopy, colonoscopy, complications of screening, pathology, and of colorectal cancer treatment are those used for the cost-effectiveness analysis of the DNA stool test for CMS (25).

Briefly, screening-related costs were based on the set of current procedural terminology (CPT) codes relevant to CRC screening in conjunction with the points of service for the procedures. 1) in the Ambulatory Surgery Center (ASC) setting, we include the Medicare ASC facility payment and the payment for physician professional services; 2) In the Outpatient Prospective Payment System (OPPS) setting, we include the Medicare OPPS facility payment and the payment for physician services; and 3) in the office setting, we include the payment to the physician for providing the service includes both professional services and the facility costs of the physician’s office. We did not include CPT codes of inpatient procedures as registered in the Inpatient Prospective Payment System because screening endoscopies are not typically performed as inpatient procedures. The total costs per CPT code were weighted by the frequencies for points of service. The total costs per screening procedure were based on the total costs per CPT code that are part of the procedure and weighted by the frequencies of the CPT codes. Payments for a procedure across these settings was represented as an average of the three settings weighted by the frequency of which each setting was used for the procedure in 2007.

### CT colonography cost per screening episode

Given that this report was written in conjunction with the National Coverage Determination for CT colonography for CRC screening in the Medicare population, there is no national CMS payment rate for a screening CT colonography at this time. Accordingly, we use as a proxy the national average CMS payment for an abdominal CT without contrast (CPT code 74150), a pelvic CT without contrast (CPT code 72192) and image processing on an independent workstation (CPT 76377). We obtained estimates of the 2008 rates from CMS for these procedures and converted them to 2007 dollars using a decrease of 3.5% in medical care costs to be compatible with the 2007 cost estimates obtained for other screening tests, complications, and colorectal cancer care. This process yielded a base-case cost for CT colonography of $488.29. We note that this is similar to the average payment for a diagnostic CT colonography among carriers in the NY area ($486) (personal communication, Bill Larson, Paul Deutch) including professional and technical fees and to an estimate by Pam Kassing of the American College of Radiology of $487.69.

This base case cost estimate of CT colonography of $488.29 does not include costs for further radiological evaluations for extracolonic findings. We note that our analyses were based on a Medicare perspective and with Medicare payments, but that in other settings colonoscopy and CT colonography costs may be very different. For example Pickhardt (72) noted that in his institution the CT colonography charge was $1187 and three to four times less than the colonoscopy charge $3323–$5000).

Table 4 Screening tests costs based on CMS payment (2007 US dollars)

Screening test | CMS cost, $^*^ | Modified societal cost,^**^ $
CT colonography^†,*^ | 488.29 | 643.64
Guaiac Hemoccult (II or SENSA) | 4.54 | 21.54
Fecal immunochemical test | 22.22 | 39.22
Flexible sigmoidoscopy | 160.78 | 270.30
Flexible sigmoidoscopy with biopsy | 348.19 | 497.37
Colonoscopy without polypectomy ‡ | 497.59 | 794.94
Colonoscopy with polypectomy or biopsy^‡^ | 648.52 | 979.28

* CMS cost represents approximately 80% of the allowable charge in 2007 dollars.

** Modified societal costs include beneficiary costs (co-payments) and time costs in addition to the payer costs

† Based on CMS payment for CT of the abdomen (CPT 74150), CT of the pelvis (CPT 72192), and image processing on an independent workstation (CPT 76377).

‡ Base case cost for colonoscopy does not include additional anesthesia costs. A secondary sensitivity analysis considers an additional $74 cost added to colonoscopy for anesthesia in 29% and 100% of colonoscopies

### Screening costs for non-CT colonography tests

Payer cost for Hemoccult II, Hemoccult SENSA, and fecal immunochemical testing do not include additional charges for points of service because these costs are related only to the clinical laboratory fee schedule (http://www.cms.hhs.gov/ClinicalLabFeeSched/).

The costs for colonoscopy without polypectomy were based on CPT codes 45378 (diagnostic colonoscopy), G0105 (colon screen in high risk individuals) and G0121 (colon cancer screening for non high risk individual). Costs for colonoscopy with polypectomy or biopsy were composed of codes 45380 (colonoscopy and biopsy), 45381 (colonoscopy, submucous injection), 45382 (colonoscopy/control bleeding), 45383 (lesion removal colonoscopy – fulguration), 45384 (lesion removal colonoscopy-hot biopsy) and 45385 (lesion removal colonoscopy-snare polypectomy). As noted above, if the colon is not adequately visualized, a repeat colonoscopy is typically performed. CMS reimburses the second colonoscopy at the same rate as for the initial colonoscopy. We assumed 5% of the colonoscopies are incomplete and need to be repeated. Instead of modeling incomplete colonoscopies, we increased the costs of a colonoscopy without polypectomy ($497.59) by 5%, resulting in $522.47. For colonoscopy with polypectomy we added the same absolute difference of $25, resulting in $673.4 (648.52 + 25). The additional $25 reflects repeat colonoscopies assuming that polyps were only removed at one of the two colonoscopies.

We assumed that polypectomy was not performed with flexible sigmoidoscopy screening. However, we distinguished flexible sigmoidoscopy with and without biopsy. For flexible sigmoidoscopy without biopsy we used CPT codes 45330 (diagnostic sigmoidoscopy) and G0104 (CA screen; flexi sigmoidoscope). Flexible sigmoidoscopy with biopsy was based on CPT code 45331 (sigmoidoscopy and biopsy).

### Polyp removal and pathology review

For the procedures with polypectomy or biopsy we included a pathology charge (CPT code 88305). The Medicare payment rates per jar were $82.40 for the Physician fee schedule office and ASC settings, and $51.59 for the OPPS setting. We assumed that all biopsies and removed polyps are reviewed by pathology and that a separate jar is submitted to pathology for each of 4 colon segments so that the resection area could be identified should the patient require surgery. Data from the National Colonoscopy Study were used to provide the estimate of 1.38 as the average number of jars per patient with polyps (hyperplastic, other polyps, and adenomas) (personal communication, Ann Zauber, Ph.D.). Consequently, we multiplied the pathology fee by 1.38 to obtain the average pathology cost associated with colonoscopy with polypectomy.

Multiple polyps requiring the same type of polypectomy removal within a single colonoscopy do not add an incremental charge to the procedure. However if different types of polypectomy are required in removing multiple polyps then CMS reimburses 100% for the most expensive procedure and 50% of the facility cost for the second procedure. As a simplifying assumption we use the weights of procedures by CPT type and do not consider different fees for different combinations of endoscopy CPT codes for polyp removal.

### Anesthesia cost for colonoscopy

For the base case the cost of moderate sedation was included in the cost of colonoscopy, assuming that it is not administered by an anesthesiologist. Some anesthesia costs such as Monitored Anesthesia Care (MAC) provided by an anesthesia professional such as an anesthesiologist or CRNA are currently being reimbursed in addition to the colonoscopy procedure. The additional CMS payment for the anesthesia was $74 based on an average cost for the CPT code 00810 in 2007 for monitored anesthesia care for lower endoscopy procedures. (The anesthesiologist receives 5 base units plus one unit for each 15 minutes of service; Joel Brill, personal communication). In 2007, 29% of colonoscopies performed outside a hospital setting for Medicare participants included an additional payment for anesthesia. We use this level as a high estimate for current anesthesia use in colorectal cancer screening. We also considered a strategy where anesthesia was reimbursed in 100% of colonoscopies as a sensitivity analysis of maximum use.

### Complications of screening

There are essentially no complications from the stool-based screening tests (Hemoccult II, Hemoccult SENSA, or immunochemical) from the tests themselves. However patients undergoing colonoscopy and, to a lesser extent, flexible sigmoidoscopy and CT colonography are at risk of experiencing complications from the procedures. Because individuals with a positive sigmoidoscopy, CT colonography or stool-based tests are referred for a follow-up colonoscopy, the complications and the associated costs are relevant and accounted for in all of the screening strategies.

Risks of complications reported in organized screening programs (73 –75) are lower than those reported for general practice colonoscopies (76, 77) and have not focused on the older ages. Also risks of complications of colonoscopy have declined over time. The major complications of colonoscopy are perforations, which can occur with or without polypectomy, serosal burns, bleeds requiring transfusion and bleeds not requiring transfusion (73, 75, 77, 78) (personal communication; Drs. John Allen and Joel Brill). Dehydration was also cited as a complication of colonoscopy in an assessment in the Medicare population (personal communication; Joan Warren, Ph.D. and Carrie Klabunde, Ph.D). All available data were used in deriving the complication rate estimates (Table 5). We used the risks and associated costs of complications with sigmoidoscopy and colonoscopy that we derived for the stool DNA report (25) in Table 5.

The costs of complications were based on the relevant diagnosis-related group (DRG) codes. For CT colonography we assumed a risk of perforation of 4.56 per 100,000 (79). Although perforations from CT colonography may be less severe than those from colonoscopy we conservatively assumed that 5.19% of those who have a perforation die as a result (80), regardless of which test caused the perforation. Some studies showed that complication rates with colonoscopy are higher in therapeutic than in purely diagnostic colonoscopies (77, 81). However, most studies do not distinguish or have too few numbers to distinguish between therapeutic and diagnostic colonoscopies. We therefore could not confidently decide on a different complication rate for therapeutic and diagnostic colonoscopies and used the same rate for both. Our assumption biases against colonoscopy screening strategies, as they have the lowest percentage of therapeutic procedures. Our estimates for colonoscopy risks are similar to the November 2008 report from a population based study in Canada by Rabeneck (82) with rates of 1.64 per 1000 for bleeding and 0.85 per 1000 for perforation. They are also consistent with the evidence review by Whitlock (38, 39) who stated that complication rates could not be derived for colonoscopies with and without polypectomy because of reporting limitations. Earlier reports on CT colonography perforation risk were in cohorts were air insufflation was the practice; current practice is to use carbon dioxide insufflation with lower risk for perforation (Dr. Zalis, personal communication).

Table 5 Summary of risks of CT colonography and endoscopy complications and costs (2007 US dollars)

Complication | Rate per 1000 | CMS cost, $ | Modified societal cost, $
With CT colonography
Perforation | 0.0456 | 12,446 | 12,712
With colonoscopy
Perforation | 0.7 | 12,446 | 12,712
Serosal burn | 0.3 | 5,208 | 5,474
Bleed with transfusion | 0.4 | 5,208 | 5,474
Bleed without transfusion | 1.1 | 320 | 586
With flexible sigmoidoscopy
Perforation | 0.02 | 12,446 | 12,712

### Costs for colorectal cancer treatment

The costs of CRC treatment were also the same as those used in the DNA stool test report (25). Briefly, these costs were derived from comparison of costs for CRC cases relative to those of matched controls in the SEER-Medicare files for the years 1998–2003 (personal communication, Robin Yabroff, Ph.D. and Martin Brown, Ph.D; (83)) and vary by phase of care (Table 6).

Table 6 Net payments for colorectal cancer care during 1998–2003 (in 2007 US dollars)^*^

AJCC Stage | Initial Phase | Continuing Phase | Last Year of Life
AJCC Stage | Initial Phase | Continuing Phase | Died from CRC | Died from Other Causes
[underlined: Direct medical costs]
I | 25,487 | 2,028 | 45,689 | 11,257
II | 35,173 | 1,890 | 45,560 | 9,846
III | 42,885 | 2,702 | 48,006 | 13,026
IV | 56,000 | 8,375 | 64,428 | 34,975
[underlined: Modified societal costs]
I | 32,720 | 2,719 | 56,640 | 17,408
II | 43,752 | 2,561 | 56,417 | 15,740
III | 53,003 | 3,573 | 59,481 | 19,413
IV | 68,853 | 10,743 | 78,227 | 44,384

* The initial phase of care is the first 12 months following diagnosis, the last-year–of-life phase is the final 12 months of life, and the continuing phase is all the months between the initial and last-year-of-life phases. Cancer-related costs in the continuing phase of care are an annual estimate.

### Follow-up costs of extracolonic findings

We did not include the additional medical costs nor potential net harms or net benefits to follow up of extracolonic findings detected by CT colonography in the base case analyses. Although the prevalence of extracolonic findings has been reported (21), (30), (31) as well as costs (72), the long-term benefit or harm of discovering and working up the various extracolonic findings is not known. The implicit assumption that we are making by not formally incorporating these costs, harms and benefits is that, conditional on a CT colonography examination being done, cost-effective approaches to follow-up care of extracolonic finding are being adopted. However it is not clear from the evidence available today whether this is a valid assumption. In the discussion, we briefly explain the potential consequences of including extracolononic findings for our cost-effectiveness analysis.

### Out-of-pocket and time costs

In a sensitivity analysis we added beneficiary costs (co-payments) and time costs to the payer costs for a modified societal perspective. We label this perspective a “modified societal perspective” because while we include the above costs, we do not incorporate productivity costs. This analysis captures costs and not charges, which are not a good reflection of the opportunity costs of resources required.

Beneficiary costs associated with screening tests were based on the CMS co-payment per point of service and type of CPT code. To incorporate patient time costs associated with CRC screening we assumed that the value of patient time was equal to the median US wage rate in 2007 from the Bureau of Labor Statistics, $16.64 per hour. We assumed that endoscopy screening requires preparation and recovery. We assumed that the time associated with a colonoscopy procedure was 8 hours, 4 hours with flexible sigmoidoscopy, and 2 hours with CT colonography. Patient time requirements for stool-based screen tests (e.g., Hemoccult II, Hemoccult SENSA, and immunochemical) were assumed to be 1 hour. For treatment of any complication associated with colonoscopy, sigmoidoscopy, or CT colonography, we assumed that patient time requirements would be on average 16 hours. We did not use a more detailed study of time costs associated with colonoscopy (84) because we wanted an equal accounting of time costs for all screening tests. Modified societal costs for screening are given in the right-hand side of Table 4.

The beneficiary costs for treatment were also derived based on the copayment and time costs. Estimated patient deductibles and coinsurance expenses were added by adjusting Part A and Part B payments with Medicare payment ratios provided by the CMS Office of the Actuary. Estimates of time costs for cancer care were from a recently published analysis of the SEER-Medicare linked data (85) and updated to 2007 dollars using the Consumer Price Index. The treatment costs that were used as model inputs for the modified societal perspective are shown in the bottom half of Table 6.

## Analysis

### Outcomes

Using the base-case inputs, we used each model to project a number of outcomes for each screening strategy. These outcomes include the number of cancers detected, life expectancy (discounted and undiscounted) and the lifetime CMS costs (discounted and undiscounted). Differences in results across models reflect the different underlying natural history models. Each model simulated at least 10 million individuals per simulated screening strategy. The results are reported as per 1000 screened.

### Incremental cost-effectiveness analysis

For each model, we ranked the 14 screening strategies (no screening, 12 non-CT colonography screening strategies, 1 candidate CT colonography strategy) by increasing effectiveness (i.e., discounted number of life-years gained compared with no screening). Strategies that were more costly and less effective than another strategy were ruled out by simple dominance. Strategies that were more costly and less effective than a combination of other strategies were ruled out by extended dominance. Remaining strategies were then rank ordered by increasing costs and effectiveness, and incremental cost-effectiveness ratios (ICERs) were calculated by dividing the incremental discounted cost by the incremental discounted life-years gained, relative to the next least expensive option. These strategies represent the set of efficient options. On a plot of costs versus life-years gained, a line that connects the efficient strategies is called the efficient frontier, and all dominated strategies (simple or extended) lie below this line (62). If the CT colonography strategy did not lie on the efficient frontier, we then determined the degree to which each of the following parameters would have to change in order for the CT colonography strategy to reach the frontier: unit cost of the CT scan, or relative adherence with CT colonography compared with other screening tests. Because the two base-case CT colonography scenarios do not represent competing options for CT colonography screening but rather two different estimates for test performance, we repeated this process separately for each CT colonography strategy.

### Threshold analyses

For each CT colonography strategy, we calculated the maximum cost of a single CT scan for the strategy to be part of the efficient frontier. There were three possible situations to consider when including a CT colonography strategy as an efficient strategy: (1) the CT colonography strategy was less effective than the least effective strategy on the efficient frontier, (2) the CT colonography strategy was more effective than the most effective strategy on the efficient frontier, and (3) the effectiveness of CT colonography strategy was intermediate to the least effective and most effective strategies on the efficient frontier. In the first case the threshold cost of a CT scan was calculated such that the total cost for the CT colonography strategy was the same as the next least effective efficient strategy (yielding an ICER of 0 for that non-CT colonography strategy). In the second case the threshold test cost was calculated such that the ICER for the CT colonography strategy compared with the most effective efficient strategy was equal to $50,000 per life-year gained. In the third case we identified the efficient strategy with lowest life-years gained that would still have more life-years gained than the CT colonography strategy. Subsequently the threshold cost was calculated such that the ICER of the CT colonography strategy was equal to the ICER of that selected strategy.

Our primary analysis for the threshold value was based on the incremental cost effectiveness ratio (62). These results are presented in the text and tables. We also considered two secondary analyses for the threshold costs. First, we calculated the cost of a single CT scan that would result in the same discounted lifetime cost as no screening. Second, we calculated the per-test cost that would allow a CT colonography strategy to have the same ACER as the colonoscopy ACER where the ACERs represent the incremental cost per life-year saved of each strategy relative to no screening

### Sensitivity analyses

We first conducted sensitivity analyses where we evaluated alternative scenarios of CT colonography in terms of test performance according to the primary reading approach (2D, 3D, or both 2D and 3D) and the minimum size polyp detected on CT colonography that will trigger a referral for optical colonoscopy. The test parameters for these sensitivity analyses are given in Table 7 and are based on data reported in the Department of Defense study (30), the National CT Colonography trial (31), and Johnson 2007 (40) studies. We also considered a hypothetical worst-case scenario that had slightly lower test characteristics than all other scenarios evaluated. The use of 2D for the primary reading of CT colonography does not represent current radiological practice and is only provided as a secondary analysis.

We also conducted sensitivity analyses where we varied relative adherence of CT colonography relative to the other CRC screening strategies. Some have suggested that CT colonography might entice a previously unscreened individual to undergo screening because it is non-invasive (21). Our base-case analysis assumes that 100% of participants adhere to recommendations for the screening tests. To test the impact of differential adherence rates on the threshold CT colonography test cost, we conducted a sensitivity analysis on adherence. We first started with a lower 50% adherence rate for all tests. We assumed that 50% of the population would be 100% adherent with a screening strategy and the other 50% would be non-adherent. Modeling adherence in this fashion allows us to evaluate the impact of enhancing screening with CT colonography in a previously unscreened segment of the population. We then allowed the overall adherence with the CT colonography strategy to increase from 50% to 55% and 62.5% (where 10% and 25% of unscreened individuals would adopt screening, respectively), and identified the corresponding CT colonography threshold costs per scan. It is assumed that those individuals would be adherent with any recommended follow-up or surveillance colonoscopy.

As noted above, we also conducted sensitivity analysis on adding the anesthesia cost to colonoscopy, 10-yearly CT colonography interval, and when starting screening at age 50 instead of age 65.

Table 7 CT colonography test characteristics

CT colonography scenario | Sensitivity^*^ by adenoma size or CRC, % | | | | Specificity+ (%)
CT colonography scenario | ≤5 mm | 6–9 mm | ≥10 mm | CRC^†^ | Specificity+ (%)
Strategies evaluated in the base-case analysis
CTC DoD 3D 6mm | -- | 83.6^**^ | 92.2 | 92.2 | 79.6
CTC NCTC 2D/3D 6mm | -- | 57.0^**^ | 84.0 | 84.0 | 88.0
Strategies evaluated in the sensitivity analysis
CTC DoD 3D 10mm | -- | -- | 92.2 | 92.2 | 96.0
CTC DoD 2D 6mm | -- | 31.9 | 75.0 | 75.0 | 93.4
CTC DoD 2D 10mm | -- | -- | 75.0 | 75.0 | 98.0
CTC NCTC 2D/3D 10mm | -- | -- | 84.0 | 84.0 | 86.0
CTC J 3D 10mm | -- | -- | 73.1 | 73.1 | 97.6
CTC J 2D 10mm | -- | -- | 72.0 | 72.0 | 98.1
CTC WC 2D/3D 6mm | -- | 30.0 | 64.0 | 64.0 | 78.0
CTC WC 2D/3D 10mm | -- | -- | 64.0 | 64.0 | 84.0

-- indicates sensitivity is not provided because size is smaller than the colonoscopy referral threshold of either 6mm or 10mm; DoD = Department of Defense study (30, 42); NCTC = National CT Colonography Trial (31); J = Johnson study(40); WC = hypothetical worst-case scenario

* Sensitivity is provided per individual for stool-based tests and per lesion for endoscopy and CT colonography tests.

† Sensitivity for CRC was assumed to be the same as for adenomas of size ≥10 mm due to the small number of colorectal cancers detected in the DoD and NCTC studies.

+ The lack of specificity with CT colonography reflects the detection of non-adenomatous polyps, artifacts, and adenomas smaller than the colonoscopy referral threshold.

** Sensitivity for CT colonography for adenomas 6-9 mm was mathematically derived from published tables as described in the text above.