# CONCLUSIONS

The results of this cost-effectiveness analysis suggest that CT colonography does provide a benefit in terms of life-years gained compared with no screening but the cost, relative to the benefit derived and to the availability and costs of other CRC tests (such as colonoscopy without polypectomy at $500), would need to be in range of $108 to $205 to be a non-dominated strategy, provided that the estimates of sensitivity and specificity as stated in the Department of Defense study (30) and National CT Colonography trial (31) are obtained in community-based screening settings. Our findings are based on the analysis of an unscreened 65-year-old cohort using a payer perspective under the assumption of a 5-yearly screening interval for CT colonography with referral to colonoscopy for 6 mm lesions or larger. Threshold costs are similar for a 50-year old cohort (range of $72 to $179) but can be somewhat higher when the analysis is performed using a modified societal perspective ($154 to $336), though these costs include beneficiary costs and time costs.

There is great potential for CT colonography as a CRC screening test in an average-risk population, especially if adherence for CT colonography is differentially higher than that of other CRC screening tests or costs less than colonoscopy. CT colonography is a rapidly evolving technology; new techniques must be evaluated in average risk population and the radiation risks and benefit of detection of extracolonic findings determined.