# BACKGROUND

Colorectal cancer (CRC) is the second most common cause of cancer-related death in the United States (1). It is estimated that 148,810 CRC cases will be diagnosed in 2008 with 49,960 deaths. The lifetime risk of being diagnosed with CRC is 5.7% for men and 5.2% for women; the lifetime risk of dying from CRC is 2.3% and 2.1% in men and women, respectively (2). Approximately 70% of CRCs are diagnosed in persons over the age of 65; more than 90% are diagnosed over the age of 50. Only one-third of cases are detected at an early, more curable stage.

The adenoma-carcinoma sequence is considered to be the primary pathway to CRC. In the 1970s the pathologist Basil Morson conceptualized that the adenoma was the precursor lesion for CRC (3). Screening for CRC, and its precursor lesion the adenomatous polyp, can effectively reduce CRC mortality. Randomized trials of CRC screening with a fecal occult blood test (FOBT) show a 15% to 33% reduction in CRC mortality with screening (4 –7) and a 20% reduction in CRC incidence (8). Observational studies also show that endoscopic polypectomy can markedly reduce CRC incidence and mortality (9, 10), and randomized controlled trials of screening with flexible sigmoidoscopy are currently in the field (11 –13). Despite this demonstrated benefit of CRC screening, participation in CRC screening is only 50% in the US population aged 50 or older (14).

The US Preventive Services Task Force (USPSTF) (15 –17), the Gastroenterology Multi-Society Task Force (18 –21), and the American Cancer Society (20 –22) advocate screening for CRC for asymptomatic average-risk individuals, starting at age 50. In 2002 the USPSTF (15) had concluded that there was insufficient information to recommend one screening strategy over another and recommended a range of screening options including FOBT, flexible sigmoidoscopy (with or without FOBT), or colonoscopy. In November 2008 the USPSTF updated their recommendations to include stopping CRC screening at age 75 for those who had had consistent negative screenings (17). They also recommended screening with a sensitive FOBT (i.e., Hemoccult SENSA or a fecal immunochemical test), flexible sigmoidoscopy with a sensitive FOBT, or colonoscopy. Hemoccult II and flexible sigmoidoscopy alone were not recommended. The USPSTF decision was informed by microsimulation modeling from two of the Cancer Intervention and Surveillance Modeling Network (CISNET) models used for this report (23).

New CRC screening tests, such as fecal immunochemical test, the DNA stool test, and computed tomography (CT) colonography have been introduced. In 2003 the MISCAN-Colon investigators provided a cost-effectiveness analysis of the fecal immunochemical test to the Agency for Healthcare Research and Quality (AHRQ) for the Centers for Medicare and Medicaid Services (CMS) to inform the decision regarding whether to cover the fecal immunochemical test and, if so, at what payment (24) http://www.cms.hhs.gov/mcd/viewtechassess.asp?where=index&id=20). In 2007, two CISNET modeling groups (MISCAN and SimCRC) conducted a similar cost-effectiveness analysis to that of fecal immunochemical test to estimate the threshold cost for a DNA stool test relative to currently established screening guidelines in response to a request for National Coverage Determination (http://www.cms.hhs.gov/mcd/viewtrackingsheet.asp?id=212) on the use of a DNA stool test-version 1.1 (the PreGen-Plus™ test) for CRC screening among average-risk individuals every 5 years (25). In this report three CISNET modeling groups conducted a cost-effectiveness analysis of CT colonography to estimate a threshold cost for CT colonography relative to currently recommended screening strategies in response to a National Coverage Analysis on the use of CT colonography for CRC screening among average-risk individuals (http://www.cms.hhs.gov/mcd/viewtrackingsheet.asp?id=220).

CT colonography (also known as “virtual colonoscopy”) was first described in 1994 by Vining (26) as a CT for the colon. The key conceptual basis for CT colonography arose when it was recognized that thin-slice contiguous abdominal CT images could be reconstructed in software to simulate visualization of the lumen of the colon and create a ‘fly-through’ display presenting polyps as prominent irregularities jutting from the colonic wall. It took a dozen years for this approach to reach the current state of technical maturity. Technological improvements have continued to refine this process. Between 2000 and 2002, commercial multi-row detector CT scanners advanced from 4-row detector devices to 8, 16 and 64-row assemblies, enabling high-speed imaging of the total abdomen within a single breath-hold, thus nearly eliminating motion artifacts that had hampered earlier efforts. Hardware and software innovations also made possible multi-planar displays and 3D dynamic simulations. A last critical contribution was the development of bowel prep procedures that optimized polyp visualization using CT colonography (27). As a colorectal cancer screening test to identify who should be referred onto colonoscopy, CT colonography is minimally invasive, visualizes the entire colon and rectum, requires no sedation, and has high sensitivity for adenomas of size 10 mm or larger or colorectal cancer. However a full cathartic preparation is required as well as stool tagging. In addition the test entails radiation exposure, a small risk of perforation, and additional investigation of extracolonic findings.

The USPSTF recently (17) reviewed the evidence for CT colonography as a screening test in the general population and found insufficient evidence to support recommending CT colonography for general population screening for CRC. The primary concerns were the unknown benefits and harms associated with extracolonic findings and the potential risks of radiation exposure with CT procedures. In contrast, the American Cancer Society, the Gastroenterology Multi-Society Task Force, and the American College of Radiology did include CT colonography for average-risk CRC screening in their guidelines (21, 28). Furthermore the American Cancer Society guidelines (21) recommended that all individuals with lesions 6 mm or larger be referred to optical colonoscopy with repeat CT colonography screening every 5 years. More recently the Blue Cross/Blue Shield Association issued a report from the Technology Evaluation Center stating that CT colonography for the purpose of colon cancer screening meets their criteria to assess whether a technology improves improve health outcomes (29).

In 1998 CMS began coverage for CRC screening in the general Medicare population. According to Section 42 CFR 410.37 of the Code of Federal Regulations, new CRC screening tests may be included for CMS coverage by publication of a National Coverage Determination. In May 2008 CMS requested a National Coverage Determination for CT colonography (http://www.cms.hhs.gov/mcd/viewtrackingsheet.asp?id=220). The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the CRC CISNET modeling groups. These groups delivered their draft report to the Medicare Evidence Development and Coverage Advisory Committee (MedCAC) meeting on November 5, 2008 and presented to the committee on November 19, 2008 for the committee’s consideration of the National Coverage Determination for CT colonography in the average-risk population. This report is the final report from the CISNET modeling groups for this request.

In this report we first summarize the evidence on the sensitivity and specificity of CT colonography in CRC screening. Using the best evidence for the test parameters, we then conduct simulations to determine what the payment from CMS to providers would have to be for CT colonography in order for it to be considered comparable to other CRC screening tests from a cost-effectiveness standpoint. To accomplish this we use microsimulation modeling to project lifetime costs, life-years gained, and cost-effectiveness ratios for various CRC screening strategies (including CT colonography strategies). To add robustness to the results we use three microsimulation models, each developed independently by modelers affiliated with CISNET (Cancer Intervention and Surveillance Modeling Network) – a modeling consortium funded by the National Cancer Institute that focuses on the use of modeling to improve our understanding of the impact of cancer control interventions (e.g., prevention, screening treatment) on population trends in incidence and mortality. The three simulation models, MISCAN, SimCRC, and CRC-SPIN, incorporate the best-available evidence on the natural history of colorectal disease and the screening test characteristics to project outcomes such as life-years gained compared with no screening. The results of the three models are compared; comparable results strengthen the credibility of the findings. The base-case analysis considers CT colonography every 5 years with referral of an individual with one or more lesions 6mm or larger to optical colonoscopy, using the test characteristics from the Department of Defense study (30) and the National CT Colonography Trial (31). We also assess several other scenarios as sensitivity analyses.