# Derivation of costs per screening test by point of service for frequency weights, CPT codes and resulting cost estimates, as reported in the CISNET report to CMS on DNA stool testing (25)

Table A.6.1 CPT codes for screening with flexible sigmoidoscopy and colonoscopy

CPT code | Description
Flexible sigmoidoscopy (no polyp)
45330 | Diagnostic sigmoidoscopy
G0104 | CA screen; flexible sigmoidoscope
Flexible sigmoidoscopy (with biopsy)^*^
45331 | Sigmoidoscopy and biopsy
Colonoscopy (without polypectomy)
45378 | Diagnostic colonoscopy
G0105 | Colon screen in high risk individuals
G0121 | Colon cancer screening for non high risk individual
Colonoscopy (with polypectomy)
45380 | Colonoscopy and biopsy
45381 | Colonoscopy, submucous injection
45382 | Colonoscopy/control bleeding
45383 | Lesion removal colonoscopy -fulguration
45384 | Lesion remove colonoscopy-hot biopsy
45385 | Lesion removal colonoscopy-snare polypectomy
Pathology
88305 | Tissue examination by pathologist

* Under the assumption that there is no polypectomy associated with flexible sigmoidoscopy.

Table A.6.2 Ambulatory surgery center (ASC) payment rates

CPT Code | ASC Payment, $ | | | PFS^*^- Facility, $ | | | Total ASC (ASC Payment + PFS), $
CPT Code
CPT Code | Total (B+M) | Beneficiary (B) | Medicare (M) | Total (B+M) | Beneficiary (B) | Medicare (M) | Beneficiary (B) | Medicare (M) | Societal Costs (B+M)
Flexible sigmoidoscopy without biopsy
45330 | NA | NA | NA | 56.0 | 11.2 | 44.8 | NA | 44.8 | NA
G0104 | NA | NA | NA | 56.0 | 11.2 | 44.8 | NA | 44.8 | NA
Flexible sigmoidoscopy with biopsy
45331 | 299.2 | 59.8 | 239.4 | 67.0 | 13.4 | 53.6 | 73.2 | 293.0 | 366.2
Colonoscopy without polypectomy
45378 | 446 | 89.2 | 356.8 | 197.0 | 39.4 | 157.6 | 128.6 | 514.4 | 643
G0105 | 446 | 111.5 | 334.5 | 197.0 | 39.4 | 157.6 | 150.9 | 492.1 | 643
G0121 | 446 | 111.5 | 334.5 | 197.0 | 39.4 | 157.6 | 150.9 | 492.1 | 643
Colonoscopy with polypectomy
45380 | 446 | 89.2 | 356.8 | 235.0 | 47.0 | 188.0 | 136.2 | 544.8 | 681
45381 | 446 | 89.2 | 356.8 | 222.0 | 44.4 | 177.6 | 133.6 | 534.4 | 668
45382 | 446 | 89.2 | 356.8 | 299.0 | 59.8 | 239.2 | 149 | 596 | 745
45383 | 446 | 89.2 | 356.8 | 307.0 | 61.4 | 245.6 | 150.6 | 602.4 | 753
45384 | 446 | 89.2 | 356.8 | 247.0 | 49.4 | 197.6 | 138.6 | 554.4 | 693
45385 | 446 | 89.2 | 356.8 | 279.0 | 55.8 | 223.2 | 145 | 580 | 725
Pathology
88305 | NA | NA | NA | NA | NA | NA | NA | NA | NA

* Physician fee schedule

Table A.6.3 Outpatient prospective payment system (OPPS) payment rates

CPT Code | OPPS Payment, $ | | | PFS- Facility, $ | | | Total OPPS (OPPS Payment + PFS), $
CPT Code
CPT Code | Total (B+M) | Beneficiary (B) | Medicare (M) | Total (B+M) | Beneficiary (B) | Medicare (M) | Beneficiary (B) | Medicare (M) | Societal Cost (B+M)
Flexible sigmoidoscopy without biopsy
45330 | 299.24 | 64.4 | 234.84 | 56 | 11.2 | 44.8 | 75.6 | 279.64 | 355.24
G0104 | 224.92 | 56.23 | 168.69 | 56 | 11.2 | 44.8 | 67.43 | 213.49 | 280.92
Flexible sigmoidoscopy with biopsy
45331 | 299.24 | 64.4 | 234.84 | 67 | 13.4 | 53.6 | 77.8 | 288.44 | 366.24
Colonoscopy without polypectomy
45378 | 538.99 | 186.06 | 352.93 | 197 | 39.4 | 157.6 | 225.46 | 510.53 | 735.99
G0105 | 446 | 111.5 | 334.5 | 197 | 39.4 | 157.6 | 150.9 | 492.1 | 643
G0121 | 446 | 111.5 | 334.5 | 197 | 39.4 | 157.6 | 150.9 | 492.1 | 643
Colonoscopy with polypectomy
45380 | 538.99 | 186.06 | 352.93 | 235 | 47 | 188 | 233.06 | 540.93 | 773.99
45381 | 538.99 | 186.06 | 352.93 | 222 | 44.4 | 177.6 | 230.46 | 530.53 | 760.99
45382 | 538.99 | 186.06 | 352.93 | 299 | 59.8 | 239.2 | 245.86 | 592.13 | 837.99
45383 | 538.99 | 186.06 | 352.93 | 307 | 61.4 | 245.6 | 247.46 | 598.53 | 845.99
45384 | 538.99 | 186.06 | 352.93 | 247 | 49.4 | 197.6 | 235.46 | 550.53 | 785.99
45385 | 538.99 | 186.06 | 352.93 | 279 | 55.8 | 223.2 | 241.86 | 576.13 | 817.99
Pathology
88305 | 32.03 | 10.84 | 21.19 | 38 | 7.6 | 30.4 | 18.44 | 51.59 | 70.03

Table A.6.4 Office payment rates

CPT Code | PFS- Office Total (B+M), $ | PFS- Office Beneficiary (B), $ | PFS- Office Medicare (M), $
Flexible sigmoidoscopy without biopsy
45330 | 124 | 24.8 | 99.2
G0104 | 124 | 24.8 | 99.2
Flexible sigmoidoscopy with biopsy
45331 | 160 | 32 | 128
Colonoscopy without polypectomy
45378 | 372 | 74.4 | 297.6
G0105 | 372 | 74.4 | 297.6
G0121 | 372 | 74.4 | 297.6
Colonoscopy with polypectomy
45380 | 442 | 88.4 | 353.6
45381 | 429 | 85.8 | 343.2
45382 | 590 | 118 | 472
45383 | 524 | 104.8 | 419.2
45384 | 436 | 87.2 | 348.8
45385 | 498 | 99.6 | 398.4
Pathology
88305 | 103 | 20.6 | 82.4

Table A.6.5 Select OPPS, ASC, and office payment rates with the addition of pathology costs (when applicable)

| Total ASC | | | | Total OPPS | | | | Total PFS
CPT Code | Beneficiary | Medicare | Beneficiary t with pathology review^†^ | Medicare with pathology review^†^ | Beneficiary | Medicare | Beneficiary with pathology review | Medicare with pathology review | Beneficiary | Medicare | Beneficiary with pathology review | Medicare with pathology review
Flexible sigmoidoscopy without biopsy
45330 | NA | NA | | | 75.6 | 279.6 | | | 24.8 | 99.2
G0104 | NA | NA | | | 67.4 | 213.5 | | | 24.8 | 99.2
Flexible sigmoidoscopy with biopsy
45331 | 73.2 | 293.0 | 101.7 | 406.7 | 77.8 | 288.4 | 103.2 | 359.6 | 32 | 128 | 60.4 | 241.7
Colonoscopy without polypectomy
45378 | 128.6 | 514.4 | | | 225.46 | 510.5 | | | 74.4 | 297.6
G0105 | 150.9 | 492.1 | | | 150.9 | 492.1 | | | 74.4 | 297.6
G0121 | 150.9 | 492.1 | | | 150.9 | 492.1 | | | 74.4 | 297.6
Colonoscopy with polypectomy
45380 | 136.2 | 544.8 | 164.6 | 658.5 | 233.1 | 540.9 | 258.5 | 612.1 | 88.4 | 353.6 | 116.8 | 467.3
45381 | 133.6 | 534.4 | 162.0 | 648.1 | 230.5 | 530.5 | 255.9 | 601.7 | 85.8 | 343.2 | 114.2 | 456.9
45382 | 149 | 596 | 177.4 | 709.7 | 245.9 | 592.1 | 271.3 | 663.3 | 118.0 | 472 | 146.4 | 585.7
45383 | 150.6 | 602.4 | 179.0 | 716.1 | 247.5 | 598.5 | 272.9 | 669.7 | 104.8 | 419.2 | 133.2 | 532.9
45384 | 138.6 | 554.4 | 167.0 | 668.1 | 235.5 | 550.5 | 260.9 | 621.7 | 87.2 | 348.8 | 115.6 | 462.5
45385 | 145 | 580 | 173.4 | 693.7 | 241.9 | 576.1 | 267.3 | 647.3 | 99.6 | 398.4 | 128.0 | 512.1

* All values shown in 2007 dollars.

† In the ASC setting pathology review is farmed out to external labs, for which PFS Office rates apply.

Table A.6.6 Percent of procedures by place of service (PoS), weights per place of service, and cost of individual procedures weighted by place of service

CPT Code | ASC %of proce- dures by PoS (a) | OPPS %of procedures by PoS (b) | Office %of proce- dures by PoS (c) | Total % (d = a+b+c) | ASC Weight* (a/d) | OPPS Weight* (b/d) | Office Weight * (c/d) | Beneficiary weighted cost by PoS^**^ (B) | Medicare weighted cost by PoS^**^ (M) | Society weighted cost by PoS (B+M)
Flexible sigmoidoscopy without biopsy
45330 | 0 | 26.22 | 43.26 | 69.48 | 0 | 0.38 | 0.62 | 43.97 | 167.29 | 211.26
G0104 | 0 | 22.08 | 72.86 | 94.94 | 0 | 0.23 | 0.77 | 34.71 | 125.78 | 160.49
Flexible sigmoidoscopy with biopsy
45331 | 24 | 27 | 16.09 | 67.09 | 0.36 | 0.40 | 0.24 | 82.17 | 348.19 | 430.37
Colonoscopy without polypectomy
45378 | 42.78 | 40.26 | 4.18 | 87.22 | 0.49 | 0.46 | 0.05 | 170.71 | 502.22 | 672.94
G0105 | 53.11 | 43.32 | 2.84 | 99.27 | 0.54 | 0.44 | 0.03 | 148.71 | 486.54 | 635.25
G0121 | 50.95 | 44.53 | 3.22 | 98.7 | 0.52 | 0.45 | 0.03 | 148.40 | 485.75 | 634.16
Colonoscopy with polypectomy
45380 | 47.26 | 38.13 | 3.29 | 88.68 | 0.53 | 0.43 | 0.04 | 192.28 | 631.47 | 823.75
45381 | 46 | 40.79 | 2.32 | 89.11 | 0.52 | 0.46 | 0.03 | 192.11 | 621.90 | 814.01
45382 | 20.35 | 29.84 | 1.8 | 51.99 | 0.39 | 0.57 | 0.03 | 215.63 | 678.79 | 894.43
45383 | 42.25 | 46.85 | 4.49 | 93.59 | 0.45 | 0.50 | 0.05 | 211.09 | 684.10 | 895.19
45384 | 47.8 | 44.6 | 3.02 | 95.42 | 0.50 | 0.47 | 0.03 | 197.39 | 639.92 | 837.31
45385 | 48.49 | 41.48 | 3.75 | 93.72 | 0.52 | 0.44 | 0.04 | 201.90 | 665.91 | 867.81

Out of ASC, OPPS, and office.

** Weighted average of costs from table 5 including pathology (if applicable) by PoS

Table A.6.7 Costs of flexible sigmoidoscopy and colonoscopy with and without polyps*

CPT Code | Beneficiary Weighted Cost by PoS PoS (B) | Medicare Weighted Cost by (M) | Society Weighted Cost by PoS (B+M) | Total number of procedures perHCPCS code | Weights by HCPCS code (w) | Weighted Beneficiary Costs by PoS and HCPCS code (w*B) | Weighted Medicare Costs by PoS and HCPCS code (w*M) | Weighted Society Costs by PoS and HCPCS code (w*(B+M))
Flexible sigmoidoscopy without biopsy
45330 | 43.97 | 167.29 | 211.26 | 74,032 | 0.84 | 37.07 | 141.06 | 178.13
G0104 | 34.71 | 125.78 | 160.49 | 13,770 | 0.16 | 5.44 | 19.73 | 25.17
Total | | | | | | 42.52 | 160.78 | 203.30
Flexible sigmoidoscopy with biopsy
45331 | 82.17 | 348.19 | 430.37 | 29,349 | 1.00 | 82.17 | 348.19 | 430.37
Total | | | | | | 82.17 | 348.19 | 430.37
Colonoscopy without polypectomy
45378 | 170.71 | 502.22 | 672.94 | 1,270,881 | 0.71 | 121.76 | 358.21 | 479.97
G0105 | 148.71 | 486.54 | 635.25 | 208,073 | 0.12 | 17.37 | 56.82 | 74.18
G0121 | 148.40 | 485.75 | 634.16 | 302860 | 0.17 | 25.22 | 82.57 | 107.79
Total | | | | | | 164.35 | 497.59 | 661.94
Colonoscopy with polypectomy
45380 | 192.28 | 631.47 | 823.75 | 879279 | 0.38 | 73.70 | 242.05 | 315.76
45381 | 192.11 | 621.90 | 814.01 | 33907 | 0.01 | 2.84 | 9.19 | 12.03
45382 | 215.63 | 678.79 | 894.43 | 12530 | 0.01 | 1.18 | 3.71 | 4.89
45383 | 211.09 | 684.10 | 895.19 | 89884 | 0.04 | 8.27 | 26.81 | 35.08
45384 | 197.39 | 639.92 | 837.31 | 381305 | 0.17 | 32.81 | 106.37 | 139.18
45385 | 201.90 | 665.91 | 867.81 | 896966 | 0.39 | 78.95 | 260.39 | 339.34
Total | | | | | | 197.75 | 648.52 | 846.28