# Results for the secondary threshold analyses

Table A4.1 Threshold analysis on CT colonography test characteristics for scenarios with a 6 mm colonoscopy referral threshold: unit cost of CT colonography screening test resulting in equal outcomes compared to other recommended CRC screening strategies for different estimates of CT colonography test characteristics

| Base cases | | Sensitivity analysis, interval 10 years | | Sensitivity analysis, test characteristics †
CTC outcome | CTC DoD 3D 6mm | CTC NCTC 2D/3D 6mm | CTC DoD 3D 6mm | CTC NCTC 2D/3D 6mm | CTC WC 2D/3D 6mm | CTC DoD 2D 6mm
On efficient frontier | 122, 196, 199 | 108, 183, 205 | 52, 266, 352 | 83, 241^‡^, 371 | 25, 83^‡^, 173 | 98, 163^‡^, 246
Cost-neutral vs. no screening | 76, 323, 398 | 105, 324, 398 | 114, 482, 599 | 143, 473, 599 | 38, 251, 336 | 112, 308, 393
Equal to colonoscopy ACER | 179, 210, 221 | 194, 227, 237 | 244, 330, 348 | 258, 339, 356 | 175, 206, 248 | 246, 328, 337

ACER = average cost-effectiveness ratio compared with no screening (calculated using discounted costs and life-years gained)

* MISCAN values in plain text; SimCRC values in italics; CRC-SPIN values in bold

† See Table 7 for the test characteristics used in these scenarios

‡ CTC strategy is on the frontier as the least effective and least costly non-dominated strategy if the cost is at most this amount

Table A4.2 Threshold analysis on CT colonography test characteristics for scenarios with a 10 mm colonoscopy referral threshold: unit cost of CT colonography screening test resulting in equal outcomes compared to other recommended CRC screening strategies for different estimates of CT colonography test characteristics

| Sensitivity analysis scenarios with 10mm colonoscopy referral thresholds
| Primary 3D reads | | 2D/3D reads | | Primary 2D reads
CTC outcome | CTC DoD 3D 10mm | CTC J 3D 10mm | CTC NCTC 2D/3D 10mm | CTC WC 2D/3D 10mm | CTC DoD 2D 10mm | CTC J 2D 10mm
On efficient frontier | 98, 132^‡^, 192^‡^ | 71, 105^‡^, 153^‡^ | 49, 90^‡^, 135^‡^ | 10, 43^‡^, 81^‡^ | 75, 110^‡^, 160^‡^ | 73, 105^‡^, 154^‡^
Cost-neutral vs. no screening | 118, 327, 329 | 106, 284, 297 | 68, 284, 309 | 43, 232, 265 | 110, 290, 301 | 107, 284, 296
Equal to colonoscopy ACER | 178, 187, 259 | 151, 167, 228 | 142, 145, 210 | 96, 115, 166 | 155, 170, 233 | 150, 167, 229

ACER = average cost-effectiveness ratio compared with no screening (calculated using discounted costs and life-years gained)

* MISCAN values in plain text; SimCRC values in italics; CRC-SPIN values in bold

† See Table 7 for the test characteristics used in these scenarios

‡ CTC strategy is on the frontier as the least effective and least costly non-dominated strategy if the cost is at most this amount

Table A4.3 Threshold analysis on CT colonography adherence: unit cost of CT colonography screening test resulting in equal outcomes compared to other recommended CRC screening strategies for different levels of adherence with CT colonography screening^*^

| Base case (CTC DoD 3D 6mm 5y) | Sensitivity Analysis on CTC Adherence^†^
CTC outcome | Adherence 50% for all strategies | CTC adherence 55% | CTC adherence 62.5%
On efficient frontier | 122, 196, 199 | 293^‡^, 360^‡^, 408^‡^ | 547^‡^, 668^‡^, 694^‡^
Cost-neutral vs. no screening | 76, 323, 398 | 76, 323, 398 | 76, 323, 398
Equal to colonoscopy ACER | 179, 210, 221 | 179, 210, 221 | 179, 210, 221

ACER = average cost-effectiveness ratio compared with no screening (calculated using discounted costs and life-years gained)

* MISCAN values in plain text; SimCRC values in italics; CRC-SPIN values in bold

† Strategies other than CTC remain at 50% adherence

‡ CTC strategy is on the frontier with an incremental cost-effectiveness ratio (ICER) of $50,000 if the cost is at least this amount

Table A4.4 Threshold analysis from modified societal perspective: unit costs for CT colonography screening test resulting in equal outcomes compared to other recommended CRC screening strategies for modified societal perspective

| Total threshold costs (includes co-payments and patient time costs) | | CMS payment rates (excludes co-payments and patient time costs)
CTC outcome | CTC DoD 3D 6mm | CTC NCTC 2D/3D 6mm | CTC DoD 3D 6mm | CTC NCTC 2D/3D 6mm
On efficient frontier | 181, 318, 332 | 154, 324, 336 | 26, 163, 177 | NT, 169, 181
Cost-neutral vs. no screening | NT, 288, 406 | 12, 321, 432 | NT, 133, 250 | NT, 166, 277
Equal to colonoscopy ACER | 215, 340, 347 | 234, 371, 372 | 60, 185, 191 | 79, 216, 217

ACER = average cost-effectiveness ratio compared with no screening (calculated using discounted costs and life-years gained); NT = no threshold found (i.e., negative CTC test cost)

* MISCAN values in plain text; SimCRC values in italics; CRC-SPIN values in bold

† CTC strategy is on the frontier as the least effective and least costly non-dominated strategy if the cost is at most this amount

Table A4.5 Threshold analysis on CT colonography adherence: unit cost of CT colonography screening test resulting in equal outcomes compared to other recommended CRC screening strategies for different levels of payment of anesthesia^*^

| Base case (CTC DoD 3D 6mm 5y) | Sensitivity Analysis on CTC Adherence^†^
CTC outcome | No payment | 29% payment | 100% payment
On efficient frontier | 122, 196, 199 | 119, 199, 204 | 114, 198, 221
Cost-neutral vs. no screening | 76, 323, 398 | 57, 307, 385 | 12, 268, 353
Equal to colonoscopy ACER | 179, 210, 221 | 186, 220, 229 | 205, 243, 250,

ACER = average cost-effectiveness ratio compared with no screening (calculated using discounted costs and life-years gained)

* MISCAN values in plain text; SimCRC values in italics; CRC-SPIN values in bold

† Strategies other than CTC remain at 50% adherence

‡ CTC strategy is on the frontier with an incremental cost-effectiveness ratio (ICER) of $50,000 if the cost is at least this amount