# Additional outcomes of the analyses: Average Cost-Effectiveness Analysis Ratios (ACER)

Table A.3.1 Discounted costs and discounted life-years gained per 1000 65-year olds and average cost-effectiveness ratios, by CRC screening scenario – MISCAN

Scenario | Discounted Costs, $ | Net Discounted Costs, $ | Discounted LYG | ACER, $/LYG
No screening | 2,714,556 | 0 | 0 | NA
HII | 2,631,879 | −82,677 | 65.7 | CS
HS | 2,715,683 | 1,127 | 81.1 | 14
FIT | 2,777,228 | 62,672 | 80.1 | 782
SIGB | 2,823,217 | 108,661 | 75.0 | 1,450
SIG | 2,810,249 | 95,693 | 76.7 | 1,247
HII + SIGB | 2,790,651 | 76,095 | 84.9 | 896
HII + SIG | 2,839,118 | 124,562 | 85.4 | 1,459
HS + SIGB | 2,859,815 | 145,259 | 88.0 | 1,651
HS + SIG | 2,907,440 | 192,884 | 87.9 | 2,194
FIT + SIGB | 3,022,139 | 307,583 | 88.1 | 3,492
FIT + SIG | 2,990,860 | 276,304 | 88.1 | 3,137
COL | 2,906,228 | 191,672 | 86.7 | 2,211
CTC DoD 3D 6mm 5y | 3,469,661 | 755,106 | 85.3 | 8,855
CTC NCTC 2D/3D 6mm 5y | 3,489,238 | 774,683 | 81.3 | 9,527

ACER = average cost-effectiveness ratio compared with no screening; LYG = life-years gained compared with no screening; NA = not applicable; CS = cost-saving

Table A.3.2 Discounted costs and discounted life-years gained per 1000 65-year olds and average cost-effectiveness ratios, by CRC screening scenario – SimCRC

Scenario | Discounted Costs, $ | Net Discounted Costs, $ | Discounted LYG | ACER, $/LYG
No screening | 2,367,514 | 0 | 0 | NA
HII | 2,082,788 | −284,726 | 59.9 | CS
HS | 2,042,708 | −324,806 | 81.1 | CS
FIT | 2,116,618 | −250,896 | 79.8 | CS
SIGB | 2,168,782 | −198,733 | 65.2 | CS
SIG | 2,151,925 | −215,589 | 69.1 | CS
HII + SIGB | 2,085,889 | −281,625 | 85.7 | CS
HII + SIG | 2,072,929 | −294,585 | 87.0 | CS
HS + SIGB | 2,151,806 | −215,708 | 92.5 | CS
HS + SIG | 2,150,786 | −216,728 | 93.0 | CS
FIT + SIGB | 2,244,313 | −123,201 | 92.3 | CS
FIT + SIG | 2,244,650 | −122,864 | 92.8 | CS
COL | 2,173,712 | −193,802 | 93.8 | CS
CTC DoD 3D 6mm 5y | 2,674,721 | 307,206 | 92.0 | 3,340
CTC NCTC 2D/3D 6mm 5y | 2,706,113 | 338,599 | 87.2 | 3,881

ACER = average cost-effectiveness ratio compared with no screening; LYG = life-years gained compared with no screening; NA = not applicable; CS = cost-saving

Table A.3.3 Discounted costs and discounted life-years gained per 1000 65-year olds and average cost-effectiveness ratios, by CRC screening scenario – CRC-SPIN

Scenario | Discounted Costs, $ | Net Discounted Costs, $ | Discounted LYG | ACER, $/LYG
No screening | 1,976,803 | 0 | 0 | NA
HII | 1,536,474 | −440,329 | 64.0 | CS
HS | 1,482,449 | −494,354 | 87.3 | CS
FIT | 1,574,679 | −402,123 | 84.7 | CS
SIGB | 1,716,321 | −260,482 | 75.8 | CS
SIG | 1,626,360 | −350,443 | 80.4 | CS
HII + SIGB | 1,656,317 | −320,486 | 92.9 | CS
HII + SIG | 1,590,434 | −386,369 | 94.5 | CS
HS + SIGB | 1,666,766 | −310,037 | 99.9 | CS
HS + SIG | 1,611,331 | −365,472 | 100.5 | CS
FIT + SIGB | 1,768,508 | −208,295 | 99.2 | CS
FIT + SIG | 1,699,373 | −277,430 | 99.9 | CS
COL | 1,600,155 | −376,648 | 105.5 | CS
CTC DoD 3D 6mm 5y | 2,156,740 | 179,938 | 101.2 | 1,777
CTC NCTC 2D/3D 6mm 5y | 2,172,677 | 195,874 | 98.0 | 1,999

ACER = average cost-effectiveness ratio compared with no screening; LYG = life-years gained compared with no screening; NA = not applicable; CS = cost-saving