# Comparison of the MISCAN, SimCRC and CRC-SPIN models on natural history outcomes at age 65

Outcome | MISCAN | SimCRC | CRC-SPIN
Adenoma prevalence, age 65: | 39.8% | 37.2% | 30.7%
Number of adenomas per 1000 by site and size, age 65
Proximal colon
≤ 5 mm | 121.2 | 171.7 | 190.2
6–9 mm | 69.9 | 186.2 | 67.8
≥ 10 mm | 61.8 | 23.9 | 40.8
Distal colon
≤ 5 mm | 134.4 | 124.2 | 124.5
6–9 mm | 77.4 | 18.2 | 44.4
≥ 10 mm | 68.4 | 41.6 | 26.7
Rectum
≤ 5 mm | 133.5 | 8.7 | 14.1
6–9 mm | 76.8 | 16.0 | 9.1
≥ 10 mm | 68.1 | 15.8 | 20.2
Distribution of adenomas by site and size, age 65 (%)
Proximal colon
≤ 5 mm | 15 | 28 | 35
6–9 mm | 9 | 31 | 13
≥ 10 mm | 8 | 4 | 8
Total | 31 | 63 | 56
Distal colon
≤ 5 mm | 17 | 20 | 23
6–9 mm | 10 | 3 | 8
≥ 10 mm | 8 | 7 | 5
Total | 35 | 30 | 36
Rectum
≤ 5 mm | 16 | 1 | 3
6–9 mm | 9 | 3 | 2
≥ 10 mm | 8 | 3 | 4
Total | 34 | 7 | 8
CRC incidence among cancer-free 65-year-old population, %
10-year
Stage I | 0.4 | 0.4 | 0.3
Stage II | 0.7 | 0.7 | 0.7
Stage III | 0.5 | 0.5 | 0.5
Stage IV | 0.5 | 0.5 | 0.3
Total | 2.1 | 2.2 | 1.8
20-year
Stage I | 0.8 | 0.8 | 0.7
Stage II | 1.6 | 1.5 | 1.4
Stage III | 1.0 | 1.0 | 1.0
Stage IV | 1.0 | 1.2 | 0.7
Total | 4.4 | 4.6 | 3.9
Lifetime
Stage I | 1.0 | 1.0 | 0.9
Stage II | 2.1 | 2.0 | 1.9
Stage III | 1.3 | 1.4 | 1.4
Stage IV | 1.3 | 1.6 | 1.0
Total | 5.7 | 6.0 | 5.3