# Model descriptions

[underlined: Microsimulation models.] The MISCAN, SimCRC, and CRC-SPIN models from the National Cancer Institute CISNET consortium were used to address the question of the cost-effectiveness of screening with CT colonography. The models used common inputs and assumptions concerning the screening tests but use their independently developed natural history models in addressing these questions.

## Appendix 1a Description of the MISCAN-COLON model for natural history and intervention

### MISCAN Model overview

MISCAN-COLON is a semi-Markov microsimulation program to simulate the effect of screening and other interventions on colorectal cancer (CRC) incidence and mortality. With microsimulation we mean that each individual in the population is simulated separately. The model is semi-Markov in the sense that:

- distributions other than exponential are possible in each disease state
- transitions in one state can depend on transitions in earlier states,
- transitions can be age and calendar time dependent

All events in the model are discrete, but the durations in each state are continuous. Hence, there are no annual transitions in the model.

The development of CRC in the model is assumed to occur according to the adenoma carcinoma sequence. This means that adenomas arise in the population, some of which eventually develop into CRC. We assume that there are two types of adenomas: progressive and non-progressive adenomas. Non-progressive adenomas can grow in size, but will never develop into a cancer. Progressive adenomas have the potential to develop into cancer, if the person in whom the adenoma develops lives long enough.

All adenomas start as a small (1–5 mm) adenoma. They can grow in size to medium (6–9 mm) and large (10+ mm) adenoma. Progressive medium and large adenomas can transform into a malignant cancer stage I, not yet giving symptoms (preclinical cancer). The cancer then progresses from stage I (localized) eventually to stage IV (distant metastasis). In each stage there is a probability of the cancer giving symptoms and being clinically detected. The time between the onset of a progressive adenoma and the clinical detection of CRC is assumed to be on average 20 years. After clinical detection a person can die of CRC, or of other causes based on the survival rate. The survival from CRC is highly dependent on the stage in which the cancer was detected.

### MISCAN Simulation of an individual

Figure 2a shows how the model generates an individual life history. First MISCAN-COLON generates a time of birth and a time of death of other causes than CRC for an individual. This is shown in the top line of figure 1a. This line constitutes the life history in the absence of CRC. Subsequently, MISCAN-COLON generates adenomas for an individual. For most individuals no adenomas are simulated, for some multiple. In this example MISCAN-Colon has generated two adenomas for the individual. The first adenoma occurs at a certain age and grows in size from small to medium and large adenoma. However this is a non-progressive adenoma, so this adenoma will never transform into cancer. The second adenoma is a progressive adenoma. After having grown to 6–9 mm, the adenoma transforms into a malignant carcinoma, causing symptons and eventually resulting in an earlier death from CRC.

Appendix Figure 1a Modeling natural history into life

In Appendix Figure 1a we represent the natural history of colorectal cancer. In this example an individual develops two adenomas in their lifetime. One of the adenomas does develop into colorectal cancer and is the person’s cause of death. The other adenoma did not progress to colorectal cancer.

The life history without CRC and the development of the two adenomas are combined into a life history in the presence of CRC. This means that the state a person is in is the same as the state of the most advanced adenoma or carcinoma present. If he dies from CRC before he dies from other causes, his death age is adjusted accordingly. The combined life history with CRC is shown in the bottom line of figure 1b.

### MISCAN Simulation of screening

The complete simulation of an individual life history in figure Appendix 1a is in a situation without screening taking place. After the model has generated a life history with CRC but without screening, screening is overlaid. This is shown in figure Appendix 1b. The first three lines show the combined life history with CRC and the development of the two adenomas from figure Appendix 1a. At the moment of screening both adenomas are present, detected and removed. This results in a combined life history for CRC and screening (bottom line), where the person is adenoma-carcinoma free after the screening intervention. Because the precursor lesion has been removed this individual does not develop CRC and will therefore not die of CRC. The moment of death is delayed until the moment of death of other causes. The benefit of screening is equal to the difference between life-years lived in a situation with screening and the situation with screening.

Appendix Figure 1b Modeling screening into life history

In Appendix Figure 1b we represent the impact that screening can have on the natural history of the adenoma-carcinoma sequence. In the case of the subject from Appendix Figure 1 with two adenomas, the subject is screened; both adenomas are detected and removed, and the subject does not die of colorectal cancer but lives longer and dies of other causes.

Many other scenarios could have occurred. A person could have developed a third adenoma after the screening moment and could still have died of CRC. Another possibility would have been that one of the adenomas was missed, but in the presented example the individual really benefited of the screening intervention.

The effectiveness of screening depends on the performance characteristics of the test performed: sensitivity, specificity and reach. In the model, one minus the specificity is defined as the probability of a positive test result in an individual irrespective of any adenomas or cancers present. For a person without any adenomas or cancers, the probability of a positive test result is therefore equal to one minus the specificity. In individuals with adenomas or cancer the probability of a positive test result is dependent on the lack of specificity and the sensitivity of the test for the present lesions. Sensitivity in the model is lesion-specific, where each adenoma or cancer contributes to the probability of a positive test result.

See the model profiler http://cisnet.cancer.gov/profiles/ for a more detailed discussion of the dwell time distributions for the adenomas and colorectal cancer.

## Appendix 1b Description of the SimCRC model for natural history and intervention model

### SimCRC Model

SimCRC overview. The SimCRC model of CRC was developed to evaluate the impact of past and future interventions on CRC incidence and mortality in the U.S. The model is population-based, meaning that it simulates the life histories of multiple cohorts of individuals of a given year of birth. These cohorts can be aggregated to yield a full cross-section of the population in a given calendar year. For this analysis, we simulated the life histories of only one cohort—those aged 65 years in 2005. SimCRC is a hybrid model, specifically it is a cross between a Markov model and a discrete event simulation. While annual (often age-specific) probabilities define the likelihood of transitioning through a series of health states, the model does not have annual cycles. Instead, the age at which a given transition takes place for each simulated individual is drawn from a cumulative probability function.

SimCRC simulation of the natural history of CRC. The SimCRC natural history model describes the progression of underlying colorectal disease (i.e., the adenoma-carcinoma sequence) among an unscreened population. Each simulated individual is assumed to be free of adenomas and CRC at birth. Over time, he is at risk of forming one or more adenomas. Each adenoma may grow in size from small (≤ 5 mm) to medium (6–9 mm) to large (≥ 10 mm). Medium and large adenomas may progress to preclinical CRC, although most will not in an individual’s lifetime. Preclinical cancers may progress in stage (I-IV) and may be detected via symptoms, becoming a clinical case. Individuals with CRC may die from their cancer or from other causes.

The SimCRC model allows for heterogeneity in growth and progression rates across multiple adenomas within an individual. While all adenomas have the potential to develop into CRC, most will not. The likelihood of adenoma growth and progression to CRC is allowed to vary by location in the colorectal tract (i.e., proximal colon vs. distal colon vs. rectum).

SimCRC simulation of screening. The screening component of the SimCRC model is superimposed on the natural history model. It allows for the detection and removal of adenomas and the diagnosis of preclinical CRC. In a screening year, a person with an underlying (i.e., undiagnosed) adenoma or preclinical cancer faces the chance that the lesion is detected based on the sensitivity of the test for adenomas by size or for cancer and the reach of the test. Individuals who do not have an underlying adenoma or preclinical cancer also face the risk of having a positive screening test (and undergoing unnecessary follow-up procedures) due to the imperfect specificity of the test. While the model does not explicitly simulate non-adenomatous polyps, they are accounted for through the specificity of the test. Additionally, individuals with false-negative screening tests (i.e., individuals with an adenoma or preclinical cancer that was missed by the screening test) may be referred for follow-up due to the detection of non-adenomatous polyps. The model incorporates the risk of fatal and non-fatal complications associated with various screening procedures. It also accounts for the fact that not all individuals are adherent with CRC screening guidelines and that adherence patterns are correlated within an individual.

See the model profiler http://cisnet.cancer.gov/profiles/ for a more detailed discussion of the transition probabilities for the adenomas and colorectal cancer.

## Appendix 1c Description of CRC-CPIN model for natural history and intervention

### Model overview

For this analysis we will use the ColoRectal Cancer Simulated Population model for Incidence and Natural history (CRC-SPIN). CRC-SPIN is a semi-Markov microsimulation program to simulate the effect of screening and other interventions on colorectal cancer (CRC) incidence and mortality. With microsimulation we mean that each individual in the population is simulated separately. The model is semi-Markov in the sense that:

- distributions other than exponential are possible in each disease state
- transitions can be age, location, and calendar time dependent

All events in the model are discrete, but the durations in each state are continuous. Hence, there are no annual transitions in the model.

The CRC-SPIN model assumes that all colorectal cancers arise from an adenoma and models shifts from adenoma initiation to preclinical and clinically detectable CRC in continuous time using four components, described below. CRC-SPIN does not model adenomas <1mm, and implicitly assume that these are unobservable.

1. Adenoma Risk: CRC-SPIN models the occurrence of 1mm adenomas with a non-homogeneous Poisson process. Risk is modeled using a log-linear model. Baseline individual-level log-risk varies across individuals and has a Normal distribution. CRC-SPIN models systematic differences in the log-risk of adenomas for men and women, and by age. Age-effects are modeled using a piecewise linear age effect on log-risk with four age-risk intervals: [20,50), [50,60), [60,70), and (70. Under the CRC-SPIN model, individuals younger than 20 are not at risk of developing 1mm adenomas. Once initiated, adenomas are assigned a location using a multinomial distribution across 6 possible sites of the large intestine (from proximal to distal, with probabilities in parenthesis): 1) cecum (0.08); 2) ascending colon (0.23); 3) transverse colon (0.24); 4) descending colon (0.12); 5) sigmoid colon (0.24); and 6) rectum (0.09).

2. Adenoma Growth: CRC-SPIN models adenoma growth as a continuous process. We assume that adenoma growth varies independently across adenomas, both within and between individuals, and we allow different adenoma growth distributions for adenomas in the colon and rectum. The growth model used by CRC-SPIN is asymmetric, with exponential growth early that slows to allow an asymptote at 50mm, the maximum adenoma size. CRC-SPIN simulates adenoma growth by first simulating the time to reach 10mm using a type 2 extreme value distribution, and then solving for growth parameters. The type 2 extreme value distribution has a long right tail but does not heavily weight small values that indicate fast growth.

3. Transition from Adenoma to Invasive Cancer: CRC-SPIN models the cumulative probability of adenoma transition up to size s as a function of location (colon or rectum) and age at adenoma initiation. For an adenoma initiated at age a in the colon of a man, the probability of transition to preclinical cancer at or before size s is given by (c(s,a) = (( [ln((1cms) + (2cm(a-50)]/ (3. where (( ) is the standard Normal cumulative distribution function. Cumulative transition probabilities for adenomas in the male rectum, and adenomas in the female colon and rectum have the same form, but with different parameters. For each adenoma, the size at transition is independently generated by simulating a Uniform[0,1] pseudodeviate and using an inverse cumulative distribution look-up.

4. Sojourn Time: Under the CRC-SPIN model, sojourn time is defined as the time from transition to preclincal cancer to clinical detection, defined as the onset of symptoms leading to detection in the absence of screening. We assume that the sojourn time of each preclinical cancer is independent and has a lognormal distribution that depends on adenoma location (colon or rectum).

Clinical Outcomes: Stage and Survival: Once a cancer becomes clinically detectable, CRC-SPIN simulates size and stage at clinical detection. We specify an overall (unconditional) distribution for tumor size at clinical detection using observed SEER size at detection from 1975–1979. We base the conditional distribution of stage given size on estimates from multinomial logistic regression models for the same SEER data. These models include linear and quadratic effects of tumor size on stage at detection. Given cancer size, we determine size during the preclinical period using an exponential model, which assumes a minimum cancer size of 0.5mm and replacement of adenoma cells with cancer cells until the cancer overtakes the adenoma.

Colorectal cancer relative survival probabilities are based on Cox proportional hazards models for relative survival applied to SEER survival data for cases diagnosed from 1975 to 1979, estimated using the CANSURV program (http://srab.cancer.gov/cansurv/). Proportional hazards models were stratified by location (colon or rectum) and AJCC stage. Age and sex were included as covariates. Age was treated as continuous, though people 25–34 were grouped with 35 year olds and people 90+ were grouped with 90 year olds due to small cell sizes. Other cause mortality uses survival probabilities based on product-limit estimates for age and birth-year cohorts from the National Center for Health Statistics Databases.

### Simulation of screening

Individual life histories are simulated assuming there is no screening for colorectal cancer. After these life histories are simulated, screening is applied, to allow comparison of events with and without screening. The effectiveness of screening depends on the performance characteristics of the test performed: sensitivity, specificity and reach (for endoscopic tests). In the model, one minus the specificity is defined as the probability of a positive test result in an individual irrespective of any adenomas or cancers present. For a person without any adenomas or cancers, the probability of a positive test result is therefore equal to one minus the specificity. In individuals with adenomas or cancer the probability of a positive test result is dependent on the lack of specificity and the sensitivity of the test for the present lesions. Sensitivity in the model is lesion-specific, where each adenoma or cancer contributes to the probability of a positive test result.

See the model profiler http://cisnet.cancer.gov/profiles/ for a more detailed discussion of the transition probabilities for the adenomas and colorectal cancer.