# ABBREVIATIONS

ACER: Average cost-effectiveness ratio
AHRQ: Agency for Healthcare Research and Quality
CISNET: Cancer Intervention and Surveillance Modeling Network
CMS: Centers for Medicare and Medicaid Services
CPT: Current procedural terminology
CRC: Colorectal cancer
CRC-SPIN: Microsimulation model of Group Health Cooperative
CT: Computed tomographic
FOBT: Fecal occult blood test
ICER: Incremental cost-effectiveness ratio
MISCAN: Microsimulation model of Memorial Sloan-Kettering Cancer Center and Erasmus MC
SEER: Surveillance, Epidemiology, and End Results Program
SimCRC: Microsimulation model of University of Minnesota and Massachusetts General Hospital
USPSTF: United States Preventive Services Task Force