# REFERENCES

1 Cancer Facts and Figures American Cancer Society. Available at: http://www.cancer.org/downloads/STT/2008CAFFfinalsecured.pdf. 2008.
2 Ries LAG, Melbert D, Krapcho M, et al. SEER Cancer Statistics Rewiew, 1975–2004. National Cancer Institute. Bethesda, MD. http://seer.cancer.gov/csr/1975-2004/ , based on November 2006 SEER data submission, posted to the SEER website, 2007. 2004.
3 Morson BC. The pathogenesis of colorectal cancer. Introduction. Major Probl Pathol. 1978;10:1-13. [pmid: 359939].
4 Mandel J, Bond J, Church T, et al. Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med. 1993;328(19):1365-1371. [pmid: 8474513].
5 Mandel JS, Church TR, Ederer F, Bond JH. Colorectal cancer mortality: effectiveness of biennial screening for fecal occult blood. J Natl Cancer Inst. 1999;91(5):434-437. [pmid: 10070942].
6 Kronborg O, Fenger C, Olsen J, Jorgensen OD, Sondergaard O. Randomised study of screening for colorectal cancer with faecal-occult-blood test. Lancet. 1996;348(9040):1467-1471. [pmid: 8942774].
7 Hardcastle JD, Chamberlain JO, Robinson MH, et al. Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. 1996;348(9040):1472-1477. [pmid: 8942775].
8 Mandel JS, Church TR, Bond JH, et al. The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. 2000;343(22):1603-1607. [pmid: 11096167].
9 Winawer SJ, Zauber AG, Ho MN, et al. Prevention of colorectal cancer by colonoscopic polypectomy. The National Polyp Study Workgroup. N Engl J Med. 1993;329(27):1977-1981. [pmid: 8247072].
10 Selby JV, Friedman GD, Quesenberry CP Jr, Weiss NS. A case-control study of screening sigmoidoscopy and mortality from colorectal cancer. N Engl J Med. 1992;326(10):653-657. [pmid: 1736103].
11 Atkin WS, Edwards R, Wardle J, et al. Design of a multicentre randomised trial to evaluate flexible sigmoidoscopy in colorectal cancer screening. J Med Screen. 2001;8(3):137-144. [pmid: 11678553].
12 Segnan N, Senore C, Andreoni B, et al. Baseline findings of the Italian multicenter randomized controlled trial of"once-only sigmoidoscopy"--SCORE. J Natl Cancer Inst. 2002;94(23):1763-1772. [pmid: 12464648].
13 Prorok PC, Andriole GL, Bresalier RS, et al. Design of the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control Clin Trials. 2000;21(6 Suppl):273S-309S. [pmid: 11189684].
14 Shapiro JA, Seeff LC, Thompson TD, Nadel MR, Klabunde CN, Vernon SW. Colorectal cancer test use from the 2005 National Health Interview Survey. Cancer Epidemiol Biomarkers Prev. 2008;17(7):1623-1630. [pmid: 18628413].
15 U.S. Preventive Services Task Force. Screening for colorectal cancer: recommendation and rationale. Ann Intern Med. 2002;137(2):129-131. [pmid: 12118971].
16 Pignone M, Rich M, Teutsch SM, Berg AO, Lohr KN. Screening for colorectal cancer in adults at average risk: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137(2):132-141. [pmid: 12118972].
17 Screening for colorectal cancer: u.s. Preventive services task force recommendation statement. Ann Intern Med. 2008;149(9):627-637. [pmid: 18838716].
18 Winawer SJ, Fletcher RH, Miller L, et al. Colorectal cancer screening: clinical guidelines and rationale. Gastroenterology. 1997;112(2):594-642. [pmid: 9024315].
19 Winawer S, Fletcher R, Rex D, et al. Colorectal cancer screening and surveillance: clinical guidelines and rationale-Update based on new evidence. Gastroenterology. 2003;124(2):544-560. [pmid: 12557158].
20 Winawer SJ, Zauber AG, Fletcher RH, et al. Guidelines for colonoscopy surveillance after polypectomy: a consensus update by the US Multi-Society Task Force on Colorectal Cancer and the American Cancer Society. Published jointly in Gastroenterology 2006; 130:1872-85 and CA Cancer J Clin. 2006;56:143-159. 2006.
21 Levin B, Lieberman DA, McFarland B, et al. Screening and surveillance for the early detection of colorectal cancer and adenomatous polyps, 2008: a joint guideline from the American Cancer Society, the US Multi-Society Task Force on Colorectal Cancer, and the American College of Radiology. Published jointly in Gastroenterology. May 2008; 134(5)1570-1595. CA Cancer J Clin. 2008;58(3):130-160. and Radiology 2008. [pmid: 18322143].
22 Smith RA, Cokkinides V, Eyre HJ. American Cancer Society guidelines for the early detection of cancer, 2006. CA Cancer J Clin. 2006;56(1):11-25. quiz 49-50. [pmid: 16449183].
23 Zauber AG, Lansdorp-Vogelaar I, Knudsen AB, Wilschut J, van Ballegooijen M, Kuntz KM. Evaluating test strategies for colorectal cancer screening: a decision analysis for the u.s. Preventive services task force. Ann Intern Med. 2008;149(9):659-669. [pmid: 18838717].
24 van Ballegooijen M, Habbema JDF, Boer R, Zauber AG, Brown ML. Report to the Agency for Healthcare Research and Quality: a comparison of the cost-effectiveness of fecal occult blood tests with different test characteristics in the context of annual screening in the Medicare population. August. 2003. Accessed January 11, 2009. http://www.cms.hhs.gov/mcd/viewtechassess.asp?where=index&id=20). 2003.
25 Zauber AG, Lansdorp-Vogelaar I, Wilschut J, Knudsen AB, van Ballegooijen M, Kuntz KM. Cost-Effectiveness of DNA Stool Testing to Screen for Colorectal Cancer: Report to AHRQ and CMS from the Cancer Intervention and Surveillance Modeling Network (CISNET) for MISCAN and SimCRC Models. Available from: https://www.cms.hhs.gov/mcd/viewtechassess.asp?from2=viewtechassess.asp&id=212&. 2007.
26 Vining DJ, Gelfand DW, Bechtold RE, Grishaw EKSRY. Technical feasibility of colon imaging with helical CT and virtual reality (abstr). AJR Am J Roentgenol. Suppl. 1994;162:104.
27 Zauber AG, Levin TR, Jaffe CC, Galen BA, Ransohoff DF, Brown ML. Implications of new colorectal cancer screening technologies for primary care practice. Med Care. 2008;46(9 Suppl 1):S138-S146. [pmid: 18725826].
28 McFarland EG, Levin B, Lieberman DA, et al. Revised colorectal screening guidelines: joint effort of the American Cancer Society U.S. Multisociety Task Force on Colorectal Cancer, and American College of Radiology. Radiology. 2008;248(3):717-720. [pmid: 18710970].
29 Blue Cross Blue Shield Association. CT Colonography (“Virtual Colonoscopy”) for Colon Cancer Screening.: Executive Summary. 2008;2008. http://www.bcbs.com/blueresources/tec. accessed January 11, 2009.
30 Pickhardt PJ, Choi JR, Hwang I, et al. Computed tomographic virtual colonoscopy to screen for colorectal neoplasia in asymptomatic adults. N Engl J Med. 2003;349(23):2191-2200. [pmid: 14657426].
31 Johnson CD, Chen MH, Toledano AY, et al. Accuracy of CT colonography for detection of large adenomas and cancers. N Engl J Med. 2008;359(12):1207-1217. [pmid: 18799557].
32 Fenlon HM, Nunes DP, Schroy PC 3rd, Barish MA, Clarke PD, Ferrucci JT. A comparison of virtual and conventional colonoscopy for the detection of colorectal polyps. N Engl J Med. 1999;341(20):1496-1503. [pmid: 10559450].
33 Yee J, Akerkar GA, Hung RK, Steinauer-Gebauer AM, Wall SD, McQuaid KR. Colorectal neoplasia: performance characteristics of CT colonography for detection in 300 patients. Radiology. 2001;219(3):685-692. [pmid: 11376255].
34 Johnson CD, Harmsen WS, Wilson LA, et al. Prospective blinded evaluation of computed tomographic colonography for screen detection of colorectal polyps. Gastroenterology. 2003;125(2):311-319. [pmid: 12891530].
35 Cotton PB, Durkalski VL, Pineau BC, et al. Computed tomographic colonography (virtual colonoscopy): a multicenter comparison with standard colonoscopy for detection of colorectal neoplasia. JAMA. 2004;291(14):1713-1719. [pmid: 15082698].
36 Rockey DC, Paulson E, Niedzwiecki D, et al. Analysis of air contrast barium enema, computed tomographic colonography, and colonoscopy: prospective comparison. Lancet. 2005;365(9456):305-311. [pmid: 15664225].
37 Mulhall BP, Veerappan GR, Jackson JL. Meta-analysis: computed tomographic colonography. Ann Intern Med. 2005;142(8):635-650. [pmid: 15838071].
38 Whitlock EP, Lin JS, Liles E, Beil TL, Fu R. Screening for colorectal cancer: a targeted, updated systematic review for the u.s. Preventive services task force. Ann Intern Med. 2008;149(9):638-658. [pmid: 18838718].
39 Whitlock EP, Lin J, Liles E, et al. Screening for colorectal cancer: an updated systematic review. Rockville, MD. Agency for Healthcare Research and Quality. 2008;2008.
40 Johnson CD, Fletcher JG, MacCarty RL, et al. Effect of slice thickness and primary 2D versus 3D virtual dissection on colorectal lesion detection at CT colonography in 452 asymptomatic adults. AJR Am J Roentgenol. 2007;189(3):672-680. [pmid: 17715116].
41 Kim SH, Lee JM, Eun HW, et al. Two- versus three-dimensional colon evaluation with recently developed virtual dissection software for CT colonography. Radiology. 2007;244(3):852-864. [pmid: 17709833].
42 Pickhardt PJ, Lee AD, Taylor AJ, et al. Primary 2D versus primary 3D polyp detection at screening CT colonography. AJR Am J Roentgenol. 2007;189(6):1451-1456. [pmid: 18029884].
43 Loeve F, Boer R, van Oortmarssen GJ, van Ballegooijen M, Habbema JDF. The MISCAN-COLON simulation model for the evaluation of colorectal cancer screening. Comput Biomed Res. 1999;32:13-33. [pmid: 10066353].
44 Loeve F, Brown ML, Boer R, van Ballegooijen M, van Oortmarssen GJ, Habbema JD. Endoscopic colorectal cancer screening: a cost-saving analysis. J Natl Cancer Inst. 2000;92(7):557-563. [pmid: 10749911].
45 Frazier AL, Colditz GA, Fuchs CS, Kuntz KM. Cost-effectiveness of screening for colorectal cancer in the general population. Jama. 2000;284(15):1954-1961. [pmid: 11035892].
46 Knudsen AB. Explaining secular trends in colorectal cancer incidence and mortality with an empirically-calibrated microsimulation model. Harvard University. 2005. 183 pages.
47 Clark JC, Collan Y, Eide TJ, et al. Prevalence of polyps in an autopsy series from areas with varying incidence of large-bowel cancer. Int J Cancer. 1985;36(2):179-186. [pmid: 4018911].
48 Blatt LJ. Polyps of the colon and rectum: incidence and distribution. Dis Colon Rectum. 1961;4:277-282.
49 Arminski TC, McLean DW. Incidence and distribution of adenomatous polyps of the colon and rectum based on 1.000 autopsy examinations. Dis Colon Rectum. 1964;7:249-261. [pmid: 14176135].
50 Vatn MH, Stalsberg H. The prevalence of polyps of the large intestine in Oslo: an autopsy study. Cancer. 1982;49(4):819-825. [pmid: 7055790].
51 Jass JR, Young PJ, Robinson EM. Predictors of presence, multiplicity, size and dysplasia of colorectal adenomas. A necropsy study in New Zealand. Gut. 1992;33:1508-1514. [pmid: 1452076].
52 Johannsen LG, Momsen O, Jacobsen NO. Polyps of the large intestine in Aarhus, Denmark. An autopsy study. Scand J Gastroenterol. 1989;24(7):799-806. [pmid: 2799283].
53 Bombi JA. Polyps of the colon in Barcelona, Spain. Cancer. 1988;61(7):1472-1476. [pmid: 3345499].
54 Williams AR, Balasooriya BA, Day DW. Polyps and cancer of the large bowel: a necropsy study in Liverpool. Gut. 1982;23(10):835-842. [pmid: 7117903].
55 Rickert RR, Auerbach O, Garfinkel L, Hammond EC, Frasca JM. Adenomatous lesions of the large bowel. Cancer. 1979;43:1847-1857. [pmid: 445371].
56 Chapman I. Adenomatous polypi of large intestine: incidence and distribution. Ann Surg. 1963;157:223-226. [pmid: 14020146].
57 Rutter CM, Yu O, Miglioretti DL. A hierarchical non-homogenous Poisson model for meta-analysis of adenoma counts. Stat Med. 2007;26(1):98-109. [pmid: 16372387].
58 Doria-Rose VP, Levin TR, Selby JV, Newcomb PA, Richert-Boe KE, Weiss NS. The incidence of colorectal cancer following a negative screening sigmoidoscopy: implications for screening interval. Gastroenterology. 2004;127(3):714-722. [pmid: 15362026].
59 Surveillance Epidemiology, and End Results (SEER) Program. (http://www.seer.cancer.gov) SEER* Stat Database: Incidence - SEER 9 Regs Public-Use, Nov2003 Sub (1973–2001), National Cancer Institute. DCCPS, Surveillance Research Program, Cancer Statistics Branch, released April 2004, based on the November 2003 submission.
60 Vogelaar I, van Ballegooijen M, Schrag D, et al. How much can current interventions reduce colorectal cancer mortality in the U.S.? Mortality projections for scenarios of risk-factor modification, screening, and treatment. Cancer. 2006;107(7):1624-1633. [pmid: 16933324].
61 Knudsen AB, Wang YC, Weinstein MC, Weeks JC, Kuntz KM. Explaining the secular trends in colorectal cancer incidence and mortality using a population-based microsimulation model [Abstract]. Med Decis Making. 2004;24.
62 Gold MR, Siegel JE, Russell LB, Weinstein MC. Cost-Effectiveness in Health and Medicine. New York (NY). Oxford University Press. 1996.
63 Morikawa T, Kato J, Yamaji Y, Wada R, Mitsushima T, Shiratori Y. A comparison of the immunochemical fecal occult blood test and total colonoscopy in the asymptomatic population. Gastroenterology. 2005;129(2):422-428. [pmid: 16083699].
64 Morikawa T, Kato J, Yamaji Y, et al. Sensitivity of immunochemical fecal occult blood test to small colorectal adenomas. Am J Gastroenterol. 2007;102(10):2259-2264. [pmid: 17617203].
65 Allison JE, Sakoda LC, Levin TR, et al. Screening for colorectal neoplasms with new fecal occult blood tests: update on performance characteristics. J Natl Cancer Inst. 2007;99(19):1462-1470. [pmid: 17895475].
66 Imperiale TF, Ransohoff DF, Itzkowitz SH, Turnbull BA, Ross ME. Fecal DNA versus fecal occult blood for colorectal-cancer screening in an average-risk population. N Engl J Med. 2004;351(26):2704-2714. [pmid: 15616205].
67 Ahlquist DA, Sargent DJ, Loprinzi CL, et al. Stool DNA and occult blood testing for screen detection of colorectal neoplasia. Ann Intern Med. 2008;149(7):441-450. W81. [pmid: 18838724].
68 Gyrd-Hansen D, Sogaard J, Kronborg O. Analysis of screening data: colorectal cancer. Int J Epidemiol. 1997;26(6):1172-1181. [pmid: 9447396].
69 Eide TJ, Stalsberg H. Polyps of the large intestine in Northern Norway. Cancer. 1978;42:2839-2848. [pmid: 728878].
70 Adam I, Ali Z, Shorthouse A. How accurate is the endoscopist's assessment of visualization of the left colon seen at flexible sigmoidoscopy?. Colorectal Dis. 2001;2.
71 van Rijn JC, Reitsma JB, Stoker J, Bossuyt PM, van Deventer SJ, Dekker E. Polyp miss rate determined by tandem colonoscopy: a systematic review. Am J Gastroenterol. 2006;101(2):343-350. [pmid: 16454841].
72 Pickhardt PJ, Hanson ME, Vanness DJ, et al. Unsuspected extracolonic findings at screening CT colonography: clinical and economic impact. Radiology. 2008;249(1):151-159. [pmid: 18796673].
73 Lieberman DA, Weiss DG, Bond JH, Ahnen DJ, Garewal H, Chejfec G. Use of colonoscopy to screen asymptomatic adults for colorectal cancer. Veterans Affairs Cooperative Study Group 380. N Engl J Med. 2000;343(3):162-168. [pmid: 10900274].
74 Regula J, Rupinski M, Kraszewska E, et al. Colonoscopy in colorectal-cancer screening for detection of advanced neoplasia. N Engl J Med. 2006;355(18):1863-1872. [pmid: 17079760].
75 Pox C, Schmiegel W, Classen M. Current status of screening colonoscopy in Europe and in the United States. Endoscopy. 2007;39(2):168-173. [pmid: 17327977].
76 Levin TR, Conell C, Shapiro JA, Chazan SG, Nadel MR, Selby JV. Complications of screening flexible sigmoidoscopy. Gastroenterology. 2002;123(6):1786-1792. [pmid: 12454834].
77 Levin TR, Zhao W, Conell C, et al. Complications of colonoscopy in an integrated health care delivery system. Ann Intern Med. 2006;145(12):880-886. [pmid: 17179057].
78 Klabunde CN, Warren JL, Ransohoff DF, Brown ML. Complications of colonoscopy in the Medicare population. Gastroenterology. Supplement 2. 2007;132:A149. (995).
79 Pickhardt PJ. Incidence of colonic perforation at CT colonography: review of existing data and implications for screening of asymptomatic adults. Radiology. 2006;239(2):313-316. [pmid: 16641348].
80 Gatto NM, Frucht H, Sundararajan V, Jacobson JS, Grann VR, Neugut AI. Risk of perforation after colonoscopy and sigmoidoscopy: a population-based study. J Natl Cancer Inst. 2003;95(3):230-236. [pmid: 12569145].
81 Tran DQ, Rosen L, Kim R, Riether RD, Stasik JJ, Khubchandani IT. Actual colonoscopy: what are the risks of perforation?. Am Surg. 2001;67(9):845-847. discussion 847-8. [pmid: 11565761].
82 Rabeneck L, Paszat LF, Hilsden RJ, et al. Bleeding and perforation after outpatient colonoscopy and their risk factors in usual clinical practice. Gastroenterology. 2008;135(6):1899-1906. 1906 e1. [pmid: 18938166].
83 Yabroff KR, Lamont EB, Mariotto A, et al. Cost of care for elderly cancer patients in the United States. J Natl Cancer Inst. 2008;100(9):630-641. [pmid: 18445825].
84 Jonas DE, Russell LB, Sandler RS, Chou J, Pignone M. Patient time requirements for screening colonoscopy. Am J Gastroenterol. 2007;102(11):2401-2410. [pmid: 17608779].
85 Yabroff KR, Davis WW, Lamont EB, et al. Patient time costs associated with cancer care. J Natl Cancer Inst. 2007;99(1):14-23. [pmid: 17202109].
86 Zalis ME, Barish MA, Choi JR, et al. CT colonography reporting and data system: a consensus proposal. Radiology. 2005;236(1):3-9. [pmid: 15987959].
87 Butterly LF, Chase MP, Pohl H, Fiarman GS. Prevalence of clinically important histology in small adenomas. Clin Gastroenterol Hepatol. 2006;4(3):343-348. [pmid: 16527698].
88 O'Brien MJ, Winawer SJ, Zauber AG, et al. The National Polyp Study. Patient and polyp characteristics associated with high-grade dysplasia in colorectal adenomas. Gastroenterology. 1990;98(2):371-379. [pmid: 2403953].
89 Soetikno RM, Kaltenbach T, Rouse RV, et al. Prevalence of nonpolypoid (flat and depressed) colorectal neoplasms in asymptomatic and symptomatic adults. Jama. 2008;299(9):1027-1035. [pmid: 18319413].
90 Lieberman D. Nonpolypoid colorectal neoplasia in the United States: the parachute is open. Jama. 2008;299(9):1068-1069. [pmid: 18319420].
91 Fidler JL, Johnson CD, MacCarty RL, Welch TJ, Hara AK, Harmsen WS. Detection of flat lesions in the colon with CT colonography. Abdom Imaging. 2002;27(3):292-300. [pmid: 12173360].
92 Park SH, Lee SS, Choi EK, et al. Flat colorectal neoplasms: definition, importance, and visualization on CT colonography. AJR Am J Roentgenol. 2007;188(4):953-959. [pmid: 17377029].
93 O'Brien MJ, Winawer SJ, Zauber AG. Flat Adenomas in the National Polyp Study (NPS) are not associated with an increased risk of high grade dysplasia initially nor during surveillance. Clinical Gastroenterology and Hepatology 2004. 2004;2:905-911.
94 Pickhardt PJ, Taylor AJ, Kim DH, Reichelderfer M, Gopal DV, Pfau PR. Screening for colorectal neoplasia with CT colonography: initial experience from the 1st year of coverage by third-party payers. Radiology. 2006;241(2):417-425. [pmid: 16982816].
95 Callstrom MR, Johnson CD, Fletcher JG, et al. CT colonography without cathartic preparation: feasibility study. Radiology. 2001;219(3):693-698. [pmid: 11376256].
96 Iannaccone R, Laghi A, Catalano C, et al. Computed tomographic colonography without cathartic preparation for the detection of colorectal polyps. Gastroenterology. 2004;127(5):1300-1311. [pmid: 15520999].
97 Pickhardt PJ. Colonic preparation for computed tomographic colonography: understanding the relative advantages and disadvantages of a noncathartic approach. Mayo Clin Proc. 2007;82(6):659-661. [pmid: 17550742].
98 Brenner DJ, Hall EJ. Computed tomography--an increasing source of radiation exposure. N Engl J Med. 2007;357(22):2277-2284. [pmid: 18046031].
99 Mettler FA Jr, Thomadsen BR, Bhargavan M, et al. Medical radiation exposure in the U.S. in 2006: preliminary results. Health Phys. 2008;95(5):502-507. [pmid: 18849682].
100 Gluecker TM, Johnson CD, Harmsen WS, et al. Colorectal cancer screening with CT colonography, colonoscopy, and double-contrast barium enema examination: prospective assessment of patient perceptions and preferences. Radiology. 2003;227(2):378-384. [pmid: 12732696].
101 Bosworth HB, Rockey DC, Paulson EK, et al. Prospective comparison of patient experience with colon imaging tests. Am J Med. 2006;119(9):791-799. [pmid: 16945615].
102 Schwartz DC, Dasher KJ, Said A, et al. Impact of a CT colonography screening program on endoscopic colonoscopy in clinical practice. Am J Gastroenterol. 2008;103(2):346-351. [pmid: 17941961].
103 Brenner DJ, Georgsson MA. Mass screening with CT colonography: should the radiation exposure be of concern?. Gastroenterology. 2005;129(1):328-337. [pmid: 16012958].
104 Fletcher RH, Pignone M. Extracolonic findings with computed tomographic colonography: asset or liability?. Arch Intern Med. 2008;168(7):685-686. [pmid: 18413549].
105 Hassan C, Pickhardt PJ, Laghi A, et al. Computed tomographic colonography to screen for colorectal cancer, extracolonic cancer, and aortic aneurysm: model simulation with cost-effectiveness analysis. Arch Intern Med. 2008;168(7):696-705. [pmid: 18413551].
106 U.S. Preventive Services Task Force. Screening: Abdominal Aortic Aneurysm. Ann Intern Med. 2005;142(3):I52. [pmid: 15684202].
107 Chin M, Mendelson R, Edwards J, Foster N, Forbes G. Computed tomographic colonography: prevalence, nature, and clinical significance of extracolonic findings in a community screening program. Am J Gastroenterol. 2005;100(12):2771-2776. [pmid: 16393234].
108 Gluecker TM, Johnson CD, Wilson LA, et al. Extracolonic findings at CT colonography: evaluation of prevalence and cost in a screening population. Gastroenterology. 2003;124(4):911-916. [pmid: 12671887].
109 Yee J, Kumar NN, Godara S, et al. Extracolonic abnormalities discovered incidentally at CT colonography in a male population. Radiology. 2005;236(2):519-526. [pmid: 16040909].
110 Xiong T, McEvoy K, Morton DG, Halligan S, Lilford RJ. Resources and costs associated with incidental extracolonic findings from CT colonogaphy: a study in a symptomatic population. Br J Radiol. 2006;79(948):948-961. [pmid: 16822798].
111 Kimberly JR, Phillips KC, Santago P, et al. Extracolonic Findings at Virtual Colonoscopy: An Important Consideration in Asymptomatic Colorectal Cancer Screening. J Gen Intern Med. 2008.
112 Sonnenberg A, Delco F, Bauerfeind P. Is virtual colonoscopy a cost-effective option to screen for colorectal cancer?. Am J Gastroenterol. 1999;94(8):2268-2274. [pmid: 10445561].
113 Ladabaum U, Song K, Fendrick AM. Colorectal neoplasia screening with virtual colonoscopy: when, at what cost, and with what national impact?. Clin Gastroenterol Hepatol. 2004;2(7):554-563. [pmid: 15224279].
114 Vijan S, Hwang I, Inadomi J, et al. The cost-effectiveness of CT colonography in screening for colorectal neoplasia. Am J Gastroenterol. 2007;102(2):380-390. [pmid: 17156139].
115 Lansdorp-Vogelaar I, van Ballegooijen M, Zauber AG, Boer R, Wilschut J, Habbema JD. At what costs will screening with CT colonography be competitive? A cost-effectiveness approach. Int J Cancer. 2008;124(5):1161-1168. [pmid: 19048626].
116 Ho C, Heitman S, Membe S, et al. (Agency for Drugs and Technologies in Health). Computed tomographic colonography for colorectal cancer screening in an average risk population: Systematic review and economic evaluation. 2008.
117 Pickhardt PJ, Nugent PA, Mysliwiec PA, Choi JR, Schindler WR. Location of adenomas missed by optical colonoscopy. Ann Intern Med. 2004;141(5):352-359. [pmid: 15353426].
118 Coups EJ, Manne SL, Meropol NJ, Weinberg DS. Multiple behavioral risk factors for colorectal cancer and colorectal cancer screening status. Cancer Epidemiol Biomarkers Prev. 2007;16(3):510-516. [pmid: 17372246].
119 Schrag D. The price tag on progress--chemotherapy for colorectal cancer. N Engl J Med. 2004;351(4):317-319. [pmid: 15269308].