# APPENDICES

Appendix 1 Model descriptions

Appendix 2 Comparison of the MISCAN, SimCRC and CRC-SPIN models on natural history outcomes at age 65

Appendix 3 Additional outcomes of the analyses: Average Cost-Effectiveness Analysis Ratios (ACER)

Appendix 4 Results for the secondary threshold analyses

Appendix 5 Results for a cohort of 50-year-olds

Appendix 6 Derivation of costs per screening test by point of service for frequency weights, CPT codes and resulting cost estimates, as reported in the CISNET report to CMS on DNA stool testing