# Acknowledgments

This report was prepared by the Office of the Surgeon General with support from the DHHS Office of Population Affairs.

- RADM Kenneth Moritsugu, M.D., M.P.H.,
- Deputy Surgeon General,
- Office of the Surgeon General

- Damon Thompson,
- Director of Communications,
- Office of the Surgeon General

- Cynthia Bennett,
- Deputy Director of Public Affairs,
- Office of the Surgeon General

- CAPT Allan S. Noonan, M.D., M.P.H.,
- Senior Advisor,
- Office of the Surgeon General

- Mireille B. Kanda, M.D., M.P.H.,
- Acting Director,
- Office of Population Affairs

- John Jarman,
- Acting Deputy Director,
- Office of Population Affairs

- Barbara Cohen,
- Policy Analyst,
- Office of Population Affairs

## Editors

- Eli Coleman, Ph.D.,
- Professor and Director,
- Program in Human Sexuality,
- Department of Family Practice and Community Health,
- University of Minnesota
- - Scientific Editor and Special Advisor

- Janet Shibley Hyde, Ph.D.,
- Professor and Chair,
- Department of Psychology,
- University of Wisconsin, Madison
- - Scientific Editor

- Michael W. Ross, Ph.D., M.P.H.,
- Professor, School of Public Health,
- University of Texas at Houston
- - Scientific Editor

## Contributors

- Hortensia Amaro, Ph.D.,
- Boston University

- John Bancroft, M.D.,
- Indiana University

- John O.G. Billy, Ph.D.,
- Battelle Institute

- Jane D. Brown, Ph.D.,
- University of North Carolina,
- Chapel Hill

- Eli Coleman, Ph.D.,
- University of Minnesota

- Jacqueline E. Darroch, Ph.D.,
- The Alan Guttmacher Institute

- John D. DeLamater, Ph.D.,
- University of Wisconsin

- J. Dennis Fortenberry, M.D.,
- Indiana University

- William N. Friedrich, M.D.,
- Mayo Clinic

- Jennifer J. Frost, D.P.H.,
- The Alan Guttmacher Institute

- Julia Heiman, Ph.D.,
- University of Washington

- Janet Shibley Hyde, Ph.D.,
- University of Wisconsin

- Michael R. Kauth, Ph.D.,
- Tulane University

- Sarah N. Keller, Ph.D.,
- Emerson College

- Douglas Kirby, Ph.D.,
- ETR Associates

- Roger J.R. Levesque, J.D., Ph.D.,
- University of Arizona

- Ilsa Lottes, Ph.D.,
- University of Maryland

- Brent C. Miller, Ph.D.,
- Utah State University

- Sumie Okazaki, Ph.D.,
- University of Illinois

- Anita Raj, Ph.D.,
- Boston University

- Michael W. Ross, Ph.D.,
- University of Texas

- Tom Smith, Ph.D.,
- University of Chicago

- William R. Stayton, Th.D.,
- Widener University

- Brian Wilcox, Ph.D.,
- University of Nebraska

- Gail Wyatt, Ph.D.,
- University of California, Los Angeles

## Steering Committee

- Julio C. Abreu,
- AIDS Action

- Christine Bachrach, Ph.D.,
- National Institute of Child Health and Human Development,

- John Bancroft, M.D.,
- Indiana University

- Calvin O. Butts, III,
- Abyssinian Baptist Church

- Barbara Cohen,
- Office of Population Affairs

- Lydia Cole,
- Colbalt Communictions

- Eli Coleman, Ph.D.,
- University of Minnesota

- Tim Cruz, M.D.,
- dr.Drew.com

- Linda Wright DeAguero, Ph.D., M.P.H.,
- Centers for Disease Control and Prevention

- Elliot Dorff, Ph.D.,
- University of Judaism

- Teresa Frydryk, M.P.H.,
- JSI Research and Training Institute

- Barbara Huberman, M.Ed.,
- Advocates for Youth

- Janet Shibley Hyde, Ph.D.,
- University of Wisconsin, Madison

- Douglas Kirby, Ph.D.,
- ETR Associates

- Sarah Kovner,
- Office of the Secretary

- RADM Arthur J. Lawrence, Ph.D., M.B.A,
- Office of Public Health and Science

- Rafael Mazin, M.D., M.P.H.,
- Pan American Health Organization

- CAPT Allan S. Noonan, M.D., M.P.H.,
- Office of the Surgeon General

- Marcy Ouellette, M.D., M.P.H.,
- Office of Population Affairs.

- Michael W. Ross, Ph.D., M.P.H.,
- University of Texas at Houston

- Rachel Ross,
- Meharry Medical College

- Denese O. Shervington, M.D., M.P.H.,
- Office of Population Affairs

- Shepherd Smith,
- Institute for Youth Development

- Randolph Wykoff, M.D.,
- Office of Disease Prevention and Health Promotion

## Newport, Rhode Island: Discussion Group Leaders

- John Bancroft, M.D.,
- Indiana University

- James Breiling, Ph.D.,
- National Institute of Mental Health

- Eli Coleman, Ph.D.,
- University of Minnesota

- Deborah Haffner, M.P.H.,
- SIECUS

- Julia Heiman, Ph.D.,
- University of Washington

- Linette Leibling, M.P.H.,
- JSI Research and Training
- Institute

- William Stayton, Th.D.,
- Widener University

- William Yarber, H.S.D.,
- Indiana University

## Warrenton, Virginia: Discussion Group Leaders

- Christine Bachrach, Ph.D.,
- National Institute for Child Health and Human Development

- John Bancroft, M.D.,
- Indiana University

- James Breiling, Ph.D.,
- National Institute of Mental Health

- Linda Dominguez, R.N., N.P.,
- Planned Parenthood of New Mexico

- Elliot Dorff, Ph.D.,
- University of Judaism

- James Keenan, S.J., Ph.D.,
- Weston Jesuit School of Theology

- Jamie Feldman, M.D., Ph.D.,
- University of Minnesota

- Bronwyn Mayden, M.S.W.,
- Campaign for Our Children

- CAPT Allan Noonan, M.D., M.P.H.,
- Office of the Surgeon General

- Shepherd Smith,
- Institute for Youth Development

- William Stayton, Th.D.,
- Widener University

- William Yarber, H.S.D.,
- Indiana University

## Reviewers

- Nicole Lurie, M.D., M.S.P.H., (former) Principal
- Deputy Assistant Secretary for Health, Office of Public Health and Science,
- USDHHS

- Beverly L. Malone, Ph.D., R.N.,
- (former) Deputy Assistant Secretary for Health,
- Office of Public Health and Science,
- USDHHS

- Numerous offices and agencies within the U.S. Department of Health and Human Services, and

- Christine Bachrach, Ph.D.,
- National Institute of Child Health and Human Development

- John Bancroft, M.D.,
- Indiana University

- Charles Cesaretti,
- Center for Sexuality and Religion

- Linda Dominguez, R.N., N.P.,
- Planned Parenthood of New Mexico

- Elliot Dorff, Ph.D.,
- University of Judaism

- James Keenan, S.J., Ph.D.,
- Weston Jesuit School of Theology

- Jamie Feldman, M.D., Ph.D.,
- University of Minnesota

- Linda Fisher, Ph.D.,
- American Association of Retired Persons

- Douglas Kirby, Ph.D.,
- ETR Associates

- Joseph McIlaney, M.D.,
- The Medical Institute for Sexual Health

- Bronwyn Mayden, M.S.W.,
- Campaign for Our Children

- Rafael Mazin, Ph.D.,
- Pan American Health Organization

- Shepherd Smith,
- Institute for Youth Development

- William Stayton, Th.D.,
- Widener University

- Francisco Sy, Ph.D.,
- Centers for Disease Control and Prevention

- Patricia F. Ware,
- P.F.W. Foundation

- William Yarber, H.S.D.,
- Indiana University