# References

Abraham M (1999) Sexual abuse in south Asian immigrant marriages Violence Against Women5:591 618
Acton G (1992) Comprehensive sexuality policy, procedures and standards. In: Crocker A, Cohen H, Kastner T. [Eds.] HIV infection and developmental disability, Baltimore:133 139
Allen JP et al (1997) Preventing teen pregnancy and academic failure: experimental evaluation of a developmentally based approach Child Development64:729 742
Amaro H et al. (2001) Cultural influences on women's sexual health. In: DiClemente RJ, Wingood GM, editors Women's sexual and reproductive health, New York:
Amaro H, Raj A (2000) On the margin: power and women's HIV risk reduction strategies Sex Roles42:723 750
American Psychiatric Association (2000) Position statement on therapies focused on attempts to change sexual orientation (reparative or conversion therapies) , Washington, DC:American Psychiatric Association.
Arnold CB, Cogswell BE (1971) A condom distribution program for adolescents: the findings of a feasibility study American Journal of Public Health61:739 750
Bancroft J (1987) A physiological approach. In: Geer JH, O'Donahue WT, editors Theories of human sexuality, New York:
Bell AP et al (1981) Sexual preference: its development in men and women , Bloomington,, IN:.
Berrill KT (1992) Anti-gay violence and victimization in the United States: an overview. In: Herek GM, Berrill KT, editors Hate crimes: confronting violence against lesbians and gay men , Newbury Park,, CA:. 19 45
Billy JOG, Moore DE (1992) A multilevel analysis of marital and nonmarital fertility in the U.S Social Forces70:977 1011
Billy JOG et al (1994) Contextual effects on the sexual behavior of adolescent women Journal of Marriage and the Family56:387 404
Bowleg L et al (2000) Gender roles, power strategies, and precautionary sexual self-efficacy: implications for Black and Latina women's HIV/AIDS protective behaviors Sex Roles42:613 636
Boyer CB et al (1997) Sexually transmitted diseases (STD) and HIV risk in heterosexual adults attending a public STD clinic: evaluation of a randomized controlled behavioral risk-reduction intervention trial AIDS11:359 367
Brewster KL et al (1993) Social context and adolescent behavior: the impact of community on the transition to sexual activity Social Forces71:713 740
Brewster KL, et al (1998) The changing impact of religion on the sexual and contraceptive behavior of adolescent women in the United States Journal of Marriage and the Family60:493 504
Browning CR, Laumann EO (1997) Sexual contact between children and adults: a life course perspective American Sociological Review62:540 560
Castaneda D (2000) The close relationship context and HIV/AIDS risk reduction among Mexican Americans Sex Roles42:551 580
Centers for Disease Control and Prevention. (1999a). Prevention of Genital HPV infection and Sequelae: Report of an External Consultant's Meeting. Atlanta: Centers for Disease Control and Prevention.
Centers for Disease Control and Prevention. (1999b). CDC surveillance summaries. MMWR.
Centers for Disease Control and Prevention. (1999c). CDC HIV/AIDS prevention research project compendium of HIV prevention interventions with evidence of effectiveness. Atlanta: Centers for Disease Control and Prevention.
Centers for Disease Control and Prevention. (2000a). A glance at the HIV epidemic. Atlanta: Centers for Disease Control and Prevention.
Centers for Disease Control and Prevention. (2000b). HIV/AIDS surveillance report, mid-year edition. 12 (No. 1).
Centers for Disease Control and Prevention. (2001a). Surveillance supplemental report. 7(No.1).
Centers for Disease Control and Prevention. HIV/AIDS-United States, 1981-2000. MMWR. (2001b);50(No. RR-9)::430-4.
Centers for Disease Control and Prevention. HIV incidence among young men who have sex with men: Baltimore, Dallas, Los Angeles, Miami, New York City, San Francisco, and Seattle, 1994-2000. MMWR. (2001c);50(No. RR-9):440-4.
Christopher FS, Roosa MW (1990) An evaluation of an adolescent pregnancy prevention program: is "just say no" enough? Family Relations39:68 72
Clark LR et al (1998) Effect of HIV counseling and testing on sexually transmitted diseases and condom use in an urban adolescent population Archives of Pediatric & Adolescent Medicine152:269 273
Cohen DA et al (1991) Condom skills education and sexually transmitted disease reinfection Journal of Sex Research28:139 144
Cohen DA et al (1992) Condoms for men, not women: results of brief promotion programs. Sexually Transmitted Diseases19:245 251
Coker AL, Hall P et al (2000) Frequency and correlates of intimate partner violence by type: physical, sexual and psychological battering American Journal of Public Health90:553 559
Comas-Diaz L (1987) Feminist therapy with mainland Puerto Rican women Psychology of Women Quarterly11:461 474
Cope KM, Kunkel D (in press) Sexual messages in teens' favorite prime-time TV programs. In: Brown JD et al., editors Sexual teens, sexual media, Mahwah,, NJ:.
Coyle KK et al. (1999) Short-term impact of Safer Choices: a multi-component school-based HIV, other STD and pregnancy prevention program Journal of School Health69(5):181 188
Croft CA, Asmussen L (1993) A developmental approach to sexuality education: implications for medical practice Journal of Adolescent Health14:109 114
Darroch JE et al (1999) Age differences between sexual partners in the United States Family Planning Perspectives31(4):160 167
Dunn ME, Alarie P (1997) Trends in sexuality education in United States and Canadian medical schools Journal of Psychology and Human Sexuality9:175 184
DuRant R et al (1997) Tobacco and alcohol use behaviors portrayed in music videos: a content analysis American Journal of Public Health87:1131 1135
DuRant RH, Sanders JM (1989) Sexual behavior and contraceptive risk taking among sexually active adolescent females Journal of Adolescent Health Care10:1 9
East PL (1996) Do adolescent pregnancy and childbearing affect younger siblings? Family Planning Perspectives28(4):148 153
Finkelhor D et al (2000) Online victimization: a report on the nation's youth , Washington, DC: National Center for Missing and Exploited Children
Fleming DT et al (1997) Herpes simplex virus type 2 in the United States 1976 to 1994 New England Journal of Medicine337:1105 1111
Forrest JD, Frost JJ (1996) The family planning attitudes and experiences of low-income women Family Planning Perspectives28:246 255
Forrest JD, Samara R (1996) Impact of publicly funded contraceptive services on unintended pregnancies and implications for Medicaid expenditures Family Planning Perspectives28:188 195
Frost J, Bolzan M (1997) The provision of public sector services by family planning agencies in 1995 Family Planning Perspectives29:6 14
Gonsiorek JC (1982) The use of diagnostic concepts in working with gay and lesbian populations. In: Gonsiorek JC, editor Homosexuality and psychotherapy: a practitioner's handbook of affirmative models, New York:.
Grady WR, Klepinger DH, Nelson-Wally A (1998) Contraceptive characteristics: the perceptions and priorities of men and women Family Planning Perspectives31(4):168 175
Grady WR, Billy JOG, Klepinger DH (1993) The influence of community characteristics on the practice of effective contraception Family Planning Perspectives25(1):4 11
Greenberg BS et al (1993) Sex content in R-rated films viewed by adolescents In: Greenberg BS et al., editors. Media, sex and the adolescent , Cresskill,, NJ:.
Greene B (1997) Ethnic minority lesbian and gay men: mental health and treatment issues In: Greene B, editor. Ethnic and cultural diversity among lesbian and gay men , Thousand Oaks,, CA:.
Grosskurth H et al (1995) Impact of improved treatment of STDs on HIV infection in rural Tanzania: randomized control trial Lancet346:530 536
Guttmacher S et al (1995) Parents' attitudes and beliefs about HIV/AIDS prevention with condom availability in New York public high schools Journal of School Health65:101 106
Haldeman, DC (1994) The practice and ethics of sexual orientation conversion therapy Journal of Consulting and Clinical Psychology62:221 227
Hawkins JD et al (1999) Preventing adolescent health-risk behaviors by strengthening protection during childhood Archives of Pediatric & Adolescent Medicine153:226 234
He H et al (1998) Violence and HIV sexual risk behaviors among female sex partners of male drug users Women and Health27:161 175
Herek GM (1993) The context of antigay violence: notes on cultural and psychological heterosexism In: Garnets LD, Kimmel DC, editors. Psychological perspectives on lesbian and gay male experiences , New York:
Hiatt RA et al (1996) Pathways to early cancer detection in the multiethnic population of the San Francisco Bay Area Health Education Quarterly23(Suppl):S10 S27
Hillis SD et al (1995) The impact of a comprehensive chlamydia prevention program in Wisconsin Family Planning Perspectives27:108 111
Hingsburger D, Harber M. (1998). The ethics of touch: establishing and maintaining boundaries in service to people with developmental disabilities. Eastman, Quebec: Diverse City Press, Inc.
Hogan DP, Kitagawa EM (1985) The impact of social status, family structure and neighborhood on the fertility of black adolescents American Journal of Sociology90:825 855
Holden GW et al (1993) Cognitive, psychosocial and reported sexual behavior differences between pregnant and nonpregnant adolescents Adolescence28:557 572
Hubbard BM et al (1998) A replication of Reducing the Risk, a theory-based sexuality curriculum for adolescents Journal of School Health68(6):243 247
Institute of Medicine. (1995). The best intentions: unintended pregnancy and the well-being of children and families. Brown SS and Eisenberg L, editors. Washington, DC: National Academy Press.
Institute of Medicine. (1997). The hidden epidemic: confronting sexually transmitted diseases. Eng TR, Butler WT, editors. Washington, DC: National Academy Press.
Institute of Medicine. (2000). No time to lose: getting more from HIV prevention. Ruiz, MS et al. editors. Washington, DC: National Academy Press.
Jaccard J, et al. Maternal correlates of adolescent sexual and contraceptive behavior. Family Planning Perspectives. (1996):159-165.
Jemmott JB et al (1992) Reductions in HIV risk-associated sexual behaviors among black male adolescents: effects of an AIDS prevention intervention American Journal of Public Health82(3):372 377
Jemmott JB et al (1998) Abstinence and safer sex: a randomized trial of HIV sexual risk-reduction interventions for young African-American adolescents Journal of the American Medical Association279(19):1529 1536
Kamb ML et al (1998) Efficacy of risk-reduction counseling to prevent human immunodeficiency virus and sexually transmitted diseases: A randomized controlled trial Journal of the American Medical Association280:1161 1167
Kegeles SM et al (1996) The Mpowerment Project: a community-level HIV intervention for young gay men American Journal of Public Health86:1129 1136
Kelly JA et al (1991) HIV risk behavior reduction following intervention with key opinion leaders of a population: an experimental community-level analysis American Journal of Public Health81:168 171
Kelly JA et al (1997) Randomized, controlled community-level HIV prevention intervention for sexual-risk behavior among homosexual men in U.S. cities Lancet350:1500 1505
Kirby D et al (1991) Reducing the risk: Impact of a new curriculum on sexual risk-taking Family Planning Perspectives23(6):253 263
Kirby D et al (1997) The impact of the postponing sexual involvement curriculum among youths in California Family Planning Perspectives29(3):100 108
Kirby D (1999) Reducing adolescent pregnancy: Approaches that work Contemporary Pediatrics16:83 94
Kirby D (2001) Emerging answers: research findings on program to reduce teen pregnancy , Washington, DC: National Campaign to Prevent Teen Pregnancy
Kirby D Brown NL (1996) Condom availability programs in U.S. schools Family Planning Perspectives28:196 202
Koss MP, Dinero TE et al (1988) Stranger and acquaintance rape: are there differences in the victim's experience? Psychology of Women Quarterly12:1 24
Ku L et al (1993) Factors influencing first intercourse for teenage men Public Health Reports108(6):680 694
Kulig JC (1994) Sexuality beliefs among Cambodians: implications for health care professionals Health Care for Women International15:69 76
Laumann EO et al (1994) The social organization of sexuality: sexual practices in the United States , Chicago:
Levesque RJR (1998) Emotional maltreatment in adolescents' everyday lives: furthering sociolegal reforms and social service provisions Behavior Sciences and the Law16:237 263
Levesque RJR (2000) Adolescents, sex, and the law: preparing adolescents for responsible citizenship , Washington, DC:
Magura S et al (1994) Outcomes of intensive AIDS education for male adolescent drug users in jail Journal of Adolescent Health15: 457 463
Main DS et al (1994) Preventing HIV infection among adolescents: evaluation of a school-based education program Preventive Medicine23:409 417
Manlove J (1998) The influence of high school dropout and school disengagement on the risk of school-age pregnancy Journal of Research on Adolescence8:187 220
Mansfield CJ et al (1993) A pilot study of AIDS education and counseling of high-risk adolescents in an office setting Journal of Adolescent Health14:115 119
Mauldon J, Luker K (1996) The effects of contraceptive education on method use at first intercourse Family Planning Perspectives28:19 24
Melchior A (1998) National evaluation of Learn and Serve American School and Community-Based Programs , Waltham,, MA:.
Miller BC (1998) Families matter: a research synthesis of family influences on adolescent pregnancy , Washington, DC:
Moore KA et al (1998) Nonmarital school-age motherhood: family, individual, and school characteristics Journal of Adolescent Research13:433 457
Olsen RJ, Farkas G (1990) The effects of economic opportunity and family background on adolescent cohabitation and childbearing among low-income blacks Journal of Labor Economics8:341 362
Remafedi G et al (1998) The relationship between suicide risk and sexual orientation: results of a population-based study American Journal of Public Health88(1):57 60
Resnick MD et al (1997) Protecting adolescents from harm: findings from the National Longitudinal Study on Adolescent Health Journal of the American Medical Association278:823 832
Roosa MW et al (1997) The relationship of childhood sexual abuse to teenage pregnancy Journal of Marriage and the Family59:119 130
Ross MW (1985) Actual and anticipated societal reaction to homosexuality and adjustment in two societies Journal of Sex Research21(1):40 55
Ross MW (1990) The relationship between life events and mental health in homosexual men Journal of Clinical Psychology46:402 411
Rotheram-Borus MJ et al (1991) Reducing HIV sexual risk behaviors among runaway adolescents Journal of the American Medical Association266(9):1237 1241
Savage OMN, Tchombe TM (1994) Anthropological perspectives on sexual behavior in Africa Annual Review of Sex Research5:50 72
Scholes D et al (1996) Prevention of pelvic inflammatory disease by screening for cervical chlamydial infection New England Journal of Medicine334(21):1362 1366
Schover L, Jensen S (1988) Sexuality and chronic illness: a comprehensive approach , New York:
Schuster MA et al (1996) The sexual practices of adolescent virgins: genital sexual activities of high school students who have never had vaginal intercourse American Journal of Public Health86:1570 1576
Sciarra JJ (1991) Infertility: a global perspective on the role of infection Annals of the New York Academy of Sciences626: 478 483
Shain RN et al (1999) A randomized, controlled trial of a behavioral intervention to prevent sexually transmitted diseases among minority women New England Journal of Medicine340:93 100
Sipski M, Alexander C (1997) Sexual function in people with disability and chronic illness: a health professional's guide , Gaithersburg,, MD:.
Smith T. (2000). Data from the general social survey. National Opinion Research Center, University of Chicago.
St Lawrence JS et al (1995) Cognitive-behavioral intervention to reduce African American adolescents' risk for HIV infection Journal of Consulting and Clinical Psychology 63(2):221 237
St. Pierre TL et al (1995) A 27-month evaluation of a sexual activity prevention program in Boys & Girls Clubs across the nation Family Relations44:69 77
Sudarkasa N (1997) African American families and family values. In: McAdoo HP, editor Black families, 3^rd^ed , Thousand Oaks,, CA:.
Sutton MJ et al (in press) Shaking the tree of knowledge for forbidden fruit: where adolescents learn about sexuality and contraception In: Brown JD et al., editors. Sexual teens, sexual media , Mahwah,, NJ:.
Tafoya T (1989) Pulling coyote's tale: Native American sexuality and AIDS In: Mays VM et al., editors. Primary prevention of AIDS: psychological approaches , Newbury Park,, CA:.
Tanfer K, Billy JOG, Payn B. (1999). A social behavioral model of STD acquisition among men. Final report to the National Institute of Allergy and Infectious Diseases, Grant No. 1 R01 A134360-01.
Tang TS et al (1999) The role of cultural variables in breast self-examination and cervical cancer screening behavior in young Asian women living in the United States Journal of Behavioral Medicine22:419 436
Thomas SB, Quinn SC (1991) The Tuskegee Syphilis Study, 1932 to 1972: implications for HIV education and AIDS risk education programs in the Black community American Journal of Public Health81:1498 1505
Tiongson AT (1997) Throwing the baby out with the bathwater: situating young Filipino mothers and fathers beyond the dominant discourse on adolescent pregnancy In: Root MPP, editor. Filipino Americans: transformation and identity , Thousand Oaks,, CA:.
U.S. Department of Health and Human Services (2000a) Child maltreatment 1998: Reports from the States to the National Child Abuse and Neglect Data System , Washington, DC:
U.S. Department of Health and Human Services (2000b) Tracking Healthy People 2010 , Washington, DC:
Upchurch DM et al (1999) Neighborhood and family contexts of adolescent sexual activity Journal of Marriage and the Family61:920 933
Ventura SJ et al (2000) Trends in pregnancies and pregnancy rates by outcome: estimates for the United States, 1976-96 National Center for Health Statistics, Vital Health Statistics21(56).
Walter HJ, Vaughn RD (1993) AIDS risk reduction among a multi-ethnic sample of urban high school students Journal of the American Medical Association270(6):725 730
Wenger NS et al (1992) Effect of HIV antibody testing and AIDS education on communication about HIV risk and sexual behavior: a randomized, controlled trial in college students Annals of Internal Medicine117:905 911
Werner-Wilson RJ (1998) Gender differences in adolescent sexual attitudes: the influence of individual and family factors Adolescence33:519 531
Westoff C et al (1996) Family planning and mass media efforts , Chapel Hill,, NC:.
Widmer ED (1997) Influence of older siblings on initiation of sexual intercourse Journal of Marriage and the Family59:928 938
Wolk LI, Rosenbaum R (1995) The benefits of school-based condom availability: cross-sectional analysis of a comprehensive high school-based program Journal of Adolescent Health17:184 188
Wyatt GE (1997) Stolen women: reclaiming our sexuality, taking back our lives , New York: