# References

1 Calle EE, Thun MJ, Petrelli JM, Rodriguez C, Heath CW Body mass index and mortality in a prospective cohort of U.S. adults N Engl J Med1999 Oct 7341(15) 1097 105 10511607
2 McGinnis JM, Foege WH Actual causes of death in the United States JAMA1993 Nov 10270(18) 2207 12 8411605
3 Allison DB, Fontaine KR, Manson JE, Stevens J, VanItallie TB Annual deaths attributable to obesity in the United States JAMA 1999Oct 27282(16) 1530 8
4 United States Department of Agriculture (USDA) and United States Department of Health and Human Services (HHS) Dietary guidelines for Americans, 5th ed. USDA; 2000 Home and Garden BulletinNo. 232.p. 10 12
5 HHS Healthy People 2010. 2nd ed. With understanding and improving health and objectives for improving health , Washington, (DC). U.S. Government Printing Office (GPO)2000 2 vol p. 19 3
6 USDA USDA continuing survey of food intakes by individuals, 1994-96 USDA1998
7 HHS Healthy People 2010, 2nd ed: With understanding and improving health and objectives for improving health , Washington, (DC). GPO 2000 2 vol p. 22 8, 22-9http://wonder.cdc.gov/data2010/
8 HHS Healthy People 2010, 2nd ed: With understanding and improving health and objectives for improving health , Washington, (DC). GPO2000 2 vol p. 22 19 through 22-23
9 Centers for Disease Control and Prevention (CDC) Ten great public health achievements-United States, 1900-1999 MMWR199948(12)
10 Guyer B, Freedman MA, Strobino DM, Sondik, EJ Annual summary of vital statistics: Trends in the health of Americans during the 20th century Pediatrics2000 Dec106(6) 1307 17 11099582
11 National Institutes of Health (NIH), National Heart, Lung, and Blood Institute (NHLBI). Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults. HHS, Public Health Service (PHS). 1998.
12 NIH, NHLBI. Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults. HHS, PHS. 1998.
13 USDA, HHS. Dietary guidelines for Americans, 5th ed. USDA; 2000. Home and Garden Bulletin No. 232.
14 National Center for Health Statistics (NCHS), CDC CDC Growth Charts: United States , Hyattsville, (MD). NCHShttp://www.cdc.gov/growthcharts/
15 Troiano RP, Flegal KM Overweight children and adolescents: Description, epidemiology, and demographics Pediatrics1998 Mar101(3) 497 504 12224656
16 NIH, NHLBI Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults HHS, PHS 1998.
17 Sturm R, Wells KB Does obesity contribute as much to morbidity as poverty or smoking? Public Health 2001 May115(3) 229 35 11429721
18 NIH, NHLBI Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults HHS, PHS 1998. p. 12 19
19 Ford ES, Williamson DF, Liu S Weight change and diabetes incidence: Findings from a national cohort of US adults Am J Epidemiol1997 Aug 1146(3) 214 22 9247005
20 Willett WC, Manson JE, Stampfer MJ, Colditz GA, Rosner B, Speizer FE, Hennekens CH Weight, weight change, and coronary heart disease in women. Risk within the 'normal' weight range JAMA1995 Feb 8273(6) 461 65 7654270
21 Galanis DJ, Harris T, Sharp DS, Petrovitch H Relative weight, weight change, and risk of coronary heart disease in the Honolulu Heart Program Am J Epidemiol1998 Feb 15147(4) 379 86 9508105
22 Weiderpass E, Persson I, Adami HO, Magnusson C, Lindgren A, Baron JA Body size in different periods of life, diabetes mellitus, hypertension, and risk of postmenopausal endometrial cancer Cancer Causes Control2000 Feb11(2) 185 92 10710204
23 NIH, NHLBI Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults HHS, PHS 1998.p. 12 13
24 NIH, NHLBI Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults HHS, PHS 1998.p. 20 23
25 Dietz WH Health consequences of obesity in youth: Childhood predictors of adult disease Pediatrics1998 Mar101(3) Suppl 518 525 12224658
26 National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK) Statistics related to obesity and overweight , Bethesda, (MD). 1996 www.niddk.nih.gov/health/nutrit/pubs/statobes.htm
27 Wolf AM, Colditz GA Current estimates of the economic cost of obesity in the United States Obes Res1998 Mar6(2) 97 106 9545015
28 Wolf A.
29 Wolf A What is the economic case for treating obesity? Obes Res19986(S1) 2S 7S 9569170
30 Eberhardt MS, Ingram DD, Makuc DM, et al Urban and rural health chartbook. Health, United States 2001, Hyattsville, (MD). NCHS2001
31 Mokdad AH, Serdula MK, Dietz WH, Bowman BA, Marks JS, Koplan JP The spread of the obesity epidemic in the United States, 1991-1998 JAMA1999 Oct 27282(16) 1519 22 10546690
32 NCHS, CDC Prevalence of overweight and obesity among adults: United States, 1999 , Hyattsville, (MD). NCHSwww.cdc.gov/nchs/products/pubs/pubd/hestats/obese/obse99.htm
33 NCHS, CDC Prevalence of overweight among children and adolescents: United States, 1999 , Hyattsville, (MD). NCHSwww.cdc.gov/nchs/products/pubs/pubd/hestats/over99fig1.htm
34 NIH, NHLBI Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults HHS, PHS 1998.p. 8 9
35 Campaigne BN, Morrison JA, Schumann BC, Faulkner F, Lakatos E, Sprecher D, Schreiber GB Indexes of obesity and comparisons with previous national survey data in 9- and 10-year old black and white girls: National Heart, Lung, and Blood Institute Growth and Health Study J Pediatr1994 May124 675 80 8176552
36 Kimm S, Barton B, Obarzanek E, McMahon R, Sabry Z, Waclawiw M, Schreiber G, Morrison J, Similo S, Daniels S Racial divergence in adiposity during adolescence: the NHLBI Growth and Health Study Pediatrics2001 Mar107(3) E34 E40 11230615
37 HHS Healthy People 2010, 2nd ed: With understanding and improving health and objectives for improving health 2 vol, Washington, (DC). GPO2000 p. 19 12
38 NIH, NHLBI Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults HHS, PHS 1998.p. 29 41
39 NIH, NHLBI Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults HHS, PHS 1998. p. 25 26
40 NIH, NHLBI Clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults HHS, PHS 1998.
41 NIDDK Study of Health Outcomes of Weight-Loss (SHOW) trial , Bethesda, (MD). NIDDKwww.niddk.nih.gov/patient/SHOW/lookahead.htm
42 Tuomilehto J, Lindstrom J, Eriksson JG, Valle TT, Hamalainen H, Ilanne-Parikka P, Keinanen-Kinkaanniemi S, Laakso M, Louheranta A, Rastas M Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance N Engl J Med2001 May 3344(18) 1343 50 11333990
43 NIDDK Diabetes Prevention Program Diet and exercise dramatically delay type 2 diabetes. Diabetes medication metformin also effective NIDDK Press Release2001