# Steering Committee Roster

Steering Committee Roste

Agency for Healthcare Research and Quality | David Atkins
Administration for Children and Families
Head Start Bureau | Robin Brocato
Administration on Aging | Yvonne Jackson
Centers for Disease Control and Prevention
Division of Nutrition and Physical Activity | William Dietz Charlene Sanders
Division of Adolescent and School Health | Lloyd Kolbe Charlene Burgeson Casey Hannan Howell Wechsler
Centers for Medicare and Medicaid Services | John Whyte CAPT David Arday
Food and Drug Administration | Bruce Schneider Elizabeth Yetley
Health Resources and Services Administration | CAPT Laura McNally
Indian Health Service | Jean Charles-Azure
National Institutes of Health
Office of the Director | Martina Vogel-Taylor
Division of Nutrition Research Coordination | CAPT Van Hubbard Pamela Starke-Reed
National Cancer Institute | CDR Richard Troiano
National Heart, Lung, and Blood Institute | Karen Donato
National Institute of Diabetes and Digestive and Kidney Diseases | Susan Yanovski
National Institute of Child Health and Human Development | Lynne Haverkos
Office of Public Health and Science
Office of Disease Prevention and Health Promotion | Randolph Wykoff Paul Ambrose Kathryn McMurry Linda Meyers
Office of the Surgeon General | Ann Elderkin
Office of Minority Health | Violet Woo
Office on Women's Health | Wanda Jones Kathy McCarty Jonelle Rowe
President's Council on Physical Fitness and Sports | Christine Spain