# Appendix B: Federal Program Resource List

Blueprint for Action on Breastfeeding Office on Women's Health U.S. Department of Health and Human Services 200 Independence Avenue, SW., Room 730B Washington, DC 20201 Phone: (202) 690-7650 Fax: (202) 205-2631 http://www.4woman.gov/Breastfeeding/index.htm

Bright Futures in Practice Bright Futures Project HRSA/Maternal and Child Health Bureau 5600 Fishers Lane, Room 18A55 Rockville, MD 20857 Phone: (301) 443-2340 Fax: (301) 443-4842 Email: cdegraw@hrsa.gov http://www.brightfutures.org

CDC Reports and Guidelines for Overweight and Obesity NHLBI Health Information Network http://www.cdc.gov/health/obesity.htm Phone: (800) 311-3435

Clinical Guidelines on the Identification, Evaluation, and Treatment of Overweight and Obesity in Adults: The Evidence Report NHLBI Health Information Network P.O. Box 30105 Bethesda, MD 20824-0105 Phone: (301) 592-8573 Fax: (301) 592-8563 http://www.nhlbi.nih.gov/guidelines/obesity/ob_home.htm

Dietary Guidelines for Americans Phone: (888) 878-3256 http://www.health.gov/dietaryguidelines

Exercise: A Guide from the National Institute on Aging http://www.nia.nih.gov/health/pubs/nasa-exercise/index.htm

Exercise: A Video from the National Institute on Aging http://www.nia.nih.gov/exercisevideo/

5 A Day for Better Health National Cancer Institute 6130 Executive Boulevard, EPN 232 Bethesda, MD 20892-7332 Phone: (301) 496-8520 http://dccps.nci.nih.gov/5aday/

Girls and Obesity Initiative Office on Women's Health U.S. Department of Health and Human Services 200 Independence Avenue, SW., Room 730B Washington, DC 20201 Phone: (202) 690-7650 Fax: (202) 205-2631 http://www.4woman.gov/owh/education.htm

Guidance on How To Understand and Use the Nutrition Facts Panel on Food Labels U.S. Food and Drug Administration Center for Food Safety and Applied Nutrition Phone: (888) SAFEFOOD http://www.cfsan.fda.gov/~dms/foodlab.html

Guide to Clinical Preventive Services, 2nd edition, 1996 U.S. Preventive Services Task Force Phone: (800) 358-9295 http://www.ahrq.gov/clinic/uspstfix.htm

Head Start Bureau -- Administration for Children and Families Phone: (202) 205-8572 http://www2.acf.dhhs.gov/programs/hsb/

healthfinder® Gateway to Reliable Consumer Health Information on the Internet National Health Information Center U.S. Department of Health and Human Services P.O. Box 1133 Washington, DC 20013-1133 Phone: (800) 336-4797 http://www.healthfinder.gov

Healthy Children, Healthy Families, and Healthy Communities American Indian/Alaska Natives Programs Branch Administration on Children, Youth and Families Administration for Children and Families 330 C Street, SW., Room 2030 Washington, DC 20447 Phone: (877) 876-2662 Fax: (202) 205-8436

Healthy People 2010 Initiative Healthy People in Healthy Communities: A Community Planning Guide Using Healthy People 2010 Office of Disease Prevention and Health Promotion U.S. Department of Health and Human Services 200 Independence Avenue, SW., Room 738G Washington, DC 20201 Phone: (202) 401-6295 Fax: (202) 205-9478 http://www.health.gov/healthypeople/publications/HealthyCommunities2001

Healthy People 2010 Toolkit Phone: (877) 252-1200 http://www.health.gov/healthypeople/state/toolkit

Hearts N' Parks National Heart, Lung, and Blood Institute P.O. Box 30105 Bethesda, MD 20824 Phone: (301) 592-8573 Fax: (301) 592-8563 Email: NHLBIinfo@rover.nhlbi.nih.gov http://www.nhlbi.nih.gov/health/prof/heart/obesity/hrt_n_pk/index.htm

LEAN Program Tripler Army Medical Center Phone: (808) 433-6060 http://das.cs.amedd.army.mil/journal/J9725.HTM

National Breastfeeding Promotion Campaign USDA Food and Nutrition Service Phone: (800) 277-4975 http://www.fns.usda.gov/wic/content/bf/brpromo.htm

NHLBI Obesity Education Initiative NHLBI Health Information Network P.O. Box 30105 Bethesda, MD 20824-0105 Phone: (301) 592-8573 Fax: (301) 592-8563 http://www.nhlbi.nih.gov and http://rover.nhlbi.nih.gov/health/public/heart/obesity/lose_wt/

Nutrition.Gov http://www.nutrition.gov

Partnership for Healthy Weight Management Phone: (202) 326-3319 http://www.consumer.gov/weightloss/

(PATCH) CDC's Planned Approach to Community Health Phone: (770) 488-5426 http://www.cdc.gov/nccdphp/patch/index.htm

Physical Activity and Health: A Report of the Surgeon General Phone: (202) 512-1800 http://www.cdc.gov/nccdphp/sgr/sgr.htm

President's Council on Physical Fitness and Sports 200 Independence Avenue, SW., Room 738H Washington, DC 20201 Phone: (202) 690-9000 Fax: (202) 690-5211 http://www.fitness.gov

Promoting Better Health for Young People Through Physical Activity and Sports Phone: (888) 231-6405 http://www.cdc.gov/nccdphp/dash/presphysactrpt/index.htm

Sisters Together: Move More, Eat Better 1 WIN WAY Bethesda, MD 20892-3665 Phone: (202) 828-1025 or 1 (877) 946-4627 Fax: (202) 828-1028 Email: win@info.niddk.nih.gov http://www.niddk.nih.gov/health/nutrit/sisters/sisters.htm

Team Nutrition USDA Food and Nutrition Service Child Nutrition Division 3101 Park Center Drive, Room 640 Alexandria, VA 22302 Phone: (703) 305-2590 Fax: (703) 305-2879 Email: cndinternet@fns.usda.gov http://www.fns.usda.gov/cnd

USDA Food and Nutrition Service Phone: (703) 305-2286 http://www.fns.usda.gov

USDA's National Agricultural Library Phone: (301) 504-5755 http://www.nal.usda.gov

Weight-control Information Network (WIN) 1 WIN WAY Bethesda, MD 20892-3665 Phone: (202) 828-1025 or 1 (877) 946-4627 Fax: (202) 828-1028 Email: win@info.niddk.nih.gov http://www.niddk.nih.gov/health/nutrit/win.htm

WIN the Rockies (Wellness IN the Rockies) http://www.uwyo.edu/wintherockies

Wisdom Steps Health Promotion Program for Elders Office for American Indian, Alaskan Native, and Native Hawaiian Phone: (202) 619-2713 Fax: (202) 260-1012 http://www.aoa.dhhs.gov/factsheets/natams.html