# Acknowledgments

## CONTRIBUTING EDITORS

- Steven K. Galson, M.D., M.P.H.
- Rear Admiral, United States Public Health Service
- Acting Surgeon General
- Office of the Surgeon General
- Department of Health and Human Services

- Robert C. Williams, P.E., D.E.E.
- Rear Admiral, United States Public Health Service
- Acting Deputy Surgeon General
- Office of the Surgeon General
- Department of Health and Human Services

- Carol A. Romano, Ph.D., R.N., F.A.A.N.
- Rear Admiral, United States Public Health Service
- Acting Chief of Staff
- Office of the Surgeon General
- Department of Health and Human Services

- Kenneth P. Moritsugu, M.D., M.P.H.,
- Rear Admiral, United States Public Health Service (Ret.)
- Former, Acting Surgeon General
- Office of the Surgeon General
- Department of Health and Human Services

- Mary Beth Bigley, Dr.P.H., M.S.N., A.N.P.
- Acting Director of Science and Communications
- Office of the Surgeon General
- Department of Health and Human Services

- Joel Nelson, M.S.W., M.P.H.
- Lieutenant, United States Public Health Service
- Special Assistant to the Deputy Surgeon General
- Office of the Surgeon General
- Department of Health and Human Services

- Peter D. Rumm, M.D., M.P.H.
- Deputy Director, Division of General, Federal Drug Administration
- Office of the Surgeon General
- Department of Health and Human Services

- Karen A. Near, M.D., M.S.
- Former Senior Science Advisor
- Office of the Surgeon General
- Department of Health and Human Services

- Catherine Wisner, Ph.D., F.N.P.
- Former Senior Health Fellow
- Office of the Surgeon General
- Department of Health and Human Services

- Mary Jean Brown, Sc.D., R.N.
- Chief, Lead Poisoning Prevention Branch
- Division of Emergency and Environmental Health Services
- National Center for Environmental Health
- Centers for Disease Control and Prevention

- Karin Mack, Ph.D.
- Division of Unintentional Injury Prevention
- National Center for Injury Prevention and Control
- Centers for Disease Control and Prevention

- Pamela Meyer, Ph.D.
- Team Leader
- Healthy Homes Goal Team
- Coordinating Center for Environmental Health and Injury Prevention
- Centers for Disease Control and Prevention

- Sven E. Rodenbeck, Sc.D., P.E., B.C.E.E.
- Captain, United States Public Health Service
- Deputy Branch Chief
- Agency for Toxic Substances and Disease Registry

- Peter A. Briss, M.D., M.P.H.
- Captain, United States Public Health Service
- Science Officer
- Coordinating Center for Environmental Health and Injury Prevention
- Centers for Disease Control and Prevention

- Howard Frumkin, M.D., Dr.P.H.
- Director, National Center for Environmental Health/
- Agency for Toxic Substances and Disease Registry
- Centers for Disease Control and Prevention

- Tom Sinks, Ph.D.
- Deputy Director, National Center for Environmental Health/
- Agency for Toxic Substances and Disease Registry
- Centers for Disease Control and Prevention

- Sharunda Buchanan, M.S., Ph.D.
- Director, Division of Emergency and Environmental Health Services
- National Center for Environmental Health
- Centers for Disease Control and Prevention

- M. Deborah Millette, M.P.H.
- Acting Deputy Director, Division of Emergency and Environmental Health Services
- National Center for Environmental Health
- Centers for Disease Control and Prevention

- Kenneth Rose, M.P.A.
- Associate Director, National Center for Environmental Health/
- Agency for Toxic Substances and Disease Registry
- Centers for Disease Control and Prevention

- Jacquelyn Mason, Ph.D.
- Public Health Analyst
- National Center for Environmental Health/
- Agency for Toxic Substances and Disease Registry
- Centers for Disease Control and Prevention

- Susan M. Conrath, Ph.D., M.P.H.
- Captain, United States Public Health Service
- Epidemiologist
- Indoor Environments Division
- U.S. Environmental Protection Agency

- Philip Jalbert
- Radon/SIRG Team Leader
- Indoor Environments Division
- U.S. Environmental Protection Agency

- Tom Kelly
- Director, Office of Air and Radiation
- Indoor Environments Division
- U.S. Environmental Protection Agency

- Maria Doa, Ph.D.
- Director, National Program Chemical Division
- U.S. Environmental Protection Agency

- Joseph L. Wysocki, Ph.D.
- National Program Leader
- Housing and Indoor Environments
- Cooperative State Research, Education, and Extension Service
- United States Department of Agriculture

- Peter Ashley, Dr.P.H.
- Director, Policy and Standards Division
- Office of Healthy Homes and Lead Hazard Control
- U.S. Department of Housing and Urban Development

- Warren Friedman, Ph.D.
- Senior Advisor to the Director
- Office of Healthy Homes and Lead Hazard Control
- U.S. Department of Housing and Urban Development

- Emily Williams
- Interim Director, Programs Division
- Office of Healthy Homes and Lead Hazard Control
- U.S. Department of Housing and Urban Development

- Allen Dearry, Ph.D.
- Interim Associate Director, National Toxicology Program
- National Institute of Environmental Health Sciences
- National Institutes of Health

## ACKNOWLEDGMENTS

This Call to Action was prepared by the U.S. Department of Health and Human Services/Centers for Disease Control and Prevention/National Center for Environmental Health under the direction of the Office of the Surgeon General.