# References

Ahrens M. 2004. US experience with smoke alarms and other fire detection/alarm equipment. Quincy, MA. National Fire Protection Association. Available at http://fire.state.nv.us. accessed 2007 August 14.
Ahrens M. 2007. U.S. experience with smoke alarms and other fire detection/alarm equipment. Quincy, MA. National Fire Protection Association. Available at http://www.nfpa.org/itemDetail.asp?categoryID=521&itemID=18245&URL=Research%20&%20Reports/Fire%20reports/Fire%20protection%20systems. accessed 2008 August 5.
Akinbami LJ, Schoendorf KC. Trends in childhood asthma: prevalence, health care utilization, and mortality. Pediatrics. 2002;110:315-22. [pmid: 12165584].
Anderson AD, Heryford AG, Sarisky JP, Higgins C, Monroe SS, Beard RS, et al. A waterborne outbreak of Norwalk-like virus among snowmobilers—Wyoming, 2001. J Infect Dis. 2003;187:303-6. [pmid: 12552455].
Arbes SJ, Cohn RD, Yin M, Muilenberg ML, Burge HA, Friedman W, et al. House dust mite allergen in US beds: results from the first National Survey of Lead and Allergens in Housing. J Allergy Clin Immunol. 2003;111(2):408-14. [pmid: 12589364].
Ballesteros MF, Kresnow MJ. Prevalence of residential smoke alarms and fire escape plans in the U.S.: results from the Second Injury Control and Risk Survey (ICARIS-2). Publ Health Rep. 2007;122:224-31.
Barlow B, Niemirska M, Gandhi RP, Leblanc W. Ten years of experience with falls from a height in children. J Pediatr Surg. 1983;18:509-11. [pmid: 6620098].
Baum A, Valins S. Berkowitz L, editor. Architectural mediation of residential density and control: crowding and the regulation of social contact. Advances in experimental social psychology. New York. Academic Press. 1979;12:131-75.
Bell PA, Greene TC, Fisher JD, Baum A. High density and crowding. In: Environmental psychology. 5th edition. Belmont, CA. Thomson Wadsworth. 2001:293-332.
Berglund B, Lindvall T, Schwela DH, editors. 1999. Guidelines for community noise. Geneva. World Health Organization.
Bingenheimer JB, Raudenbush SW. Statistical and substantive inferences in public health: Issues in the application of multilevel models. Annu Rev Publ Health. 2004;25:53-77.
Bornehag C-G, Sundell J, Sigsgaard T. Dampness in buildings and health (DBH): report from an ongoing epidemiological investigation on the association between indoor environmental factors and health effects among children in Sweden. Indoor Air. 2004;14(suppl 7):59-66. [pmid: 15330773].
Brenner RA, Trumble AC, Smith GS, Kessler EP, Overpeck MD. Where children drown, United States, 1995. Pediatrics. 2001;108(1):85-9. [pmid: 11433058].
Brown MJ, Gardner J, Sargent J, Swartz K, Hu H, Timperi R. Effectiveness of housing policies in reducing children’s lead exposure. Am J Public Health. 2001;91:621-4. [pmid: 11291376].
Brown MJ. Costs and benefits of enforcing housing policies to prevent childhood lead poisoning. Med Decision Making. 2002;22:482-92.
Buckner JC. Understanding the impact of homelessness on children: challenges and future research directions. Am Behav Sci. 2008;51:721-36.
Buka SL, Brennan RT, Rich-Edwards JW, Raudenbush SW, Earls F. Neighborhood support and the birth weight of urban infants. Am J Epidemiol. 2003;157:1-8. [pmid: 12505884].
Burt MR, Aron LY, Lee E, Valente J. 2001. Helping America’s homeless: emergency shelter or affordable housing?. Washington, DC. The Urban Institute Press.
Burt MR, Pearson C, Montgomery AE. Community-wide strategies for preventing homelessness: recent evidence. J Prim Prev. 2007;28:213-28. [pmid: 17558555].
Casarett, Doull, editors. 1991. Toxicology: the basic science of poisons. New York. Pergamon Press.
Casteel C, Runyan CW. Runyan CW, Casteel C, editors. Leading causes of unintentional home injury in high-risk age groups. The state of home safety in America. 2nd edition. Washington, DC. Home Safety Council. 2004:61-8.
Centers for Disease Control and Prevention. 1995. A survey of the quality of water drawn from domestic wells in nine Midwest states. Atlanta. U.S. Department of Health and Human Services.
Centers for Disease Control and Prevention. Blood lead levels— United States, 1999–2002. MMWR. 2005a;54:513-6.
Centers for Disease Control and Prevention. Annual smoking-attributable mortality, years of potential life lost and productivity losses— United States 1997–2001. MMWR. 2005b;54:625-8.
Centers for Disease Control and Prevention. Unintentional non–fire-related carbon monoxide exposures—United States, 2001–2003. MMWR. 2005c;54(2):36-9.
Centers for Disease Control and Prevention. 2005d. Preventing Lead Poisoning In Young Children. Atlanta. U.S. Department of Health and Human Services.
Centers for Disease Control and Prevention. 2006. Web-based Injury Statistics Query and Reporting System (WISQARS). Atlanta. U.S. Department of Health and Human Services. Available at http://www.cdc.gov/ncipc/wisqars. accessed 2008 December 2.
Centers for Disease Control and Prevention. Carbon monoxide exposures—United States, 1999–2004. MMWR. 2007a;56(50):1309-12.
Centers for Disease Control and Prevention. 2007b. National Vital Statistics System. 2001 to 2005 nonfatal injury data. Hyattsville, MD. U.S. Department of Health and Human Services.
Centers for Disease Control and Prevention. Unintentional, non-fire-related, nonfatal carbon monoxide exposures—United States, 2004–2006. MMWR. 2008;57(33):896-9. [pmid: 18716581].
Centers for Disease Control and Prevention. undated. Private ground water wells. Atlanta. U.S. Department of Health and Human Services. Available at http://www.cdc.gov/ncidod/dpd/healthywater/privatewell.htm. accessed 2009 April 15.
Centers for Disease Control and Prevention and U.S. Department of Housing and Urban Development. 2006. Healthy housing reference manual. Atlanta. U.S. Department of Health and Human Services. Available at http://www.cdc.gov/nceh/publications/books/housing/housing.htm. accessed 2008 July 27.
Centers for Disease Control and Prevention and U.S. Department of Housing and Urban Development. 2008. Healthy housing inspection manual. Atlanta. U.S. Department of Health and Human Services. Available at http://www.cdc.gov/nceh/publications/books/inspectionmanual/. accessed 2008 July 27.
Chanda SM, Pope CN. Neurochemical and neurobehavioral effects of repeated gestational exposure to chlorpyrifos in maternal and developing rats. Pharmacol Biochem Behav. 1996;53:771-6. [pmid: 8801577].
Chevrier J, Eskenzi B, Bradman A, Fenster L, Barr D. Association between prenatal exposure to polychlorinated biphenyls and neonatal thyroid-stimulating hormone levels in a Mexican-American populations, Salinas Valley, California. Environ Health Perpect. 2007;115:1490-6.
Cohn RD, Arbes SJ Jr, Yin M, Jaramillo R, Zeldin DC. National prevalence and exposure risk for mouse allergen in US households. J Allergy Clin Immunol. 2004;113(6):1167-71. [pmid: 15208600].
Cohn RD, Arbes SJ Jr, Jaramillo R, Reid LH, Zeldin DC. National prevalence and exposure risk for cockroach allergen in U.S. households. Environ Health Perspect. 2006;114:522-6. [pmid: 16581539].
Colford JM, Roy SL, Beach MJ, Hightower A, Shaw SE, Wade TJ. A review of household drinking water intervention trials and an approach to the estimation of endemic waterborne gastroenteritis in the United States. J Water Health. 2006;4(suppl 2):71-88. [pmid: 16895086].
Committee on Health Risks of Exposure to Radiation (BEIR VI). 1999. Health effects of exposure to radon. Washington, DC. The National Academies Press.
Committee on Injury, Violence, and Poison Prevention. Policy statement: prevention of drowning in infants, children, and adolescents. Pediatrics. 2003;112:440-5. [pmid: 12897306].
Corso P, Finkelstein E, Miller T, Fiebelkorn I, Zaloshnja E. Incidence and lifetime costs of injuries in the United States. Inj Prev. 2006;12:212-18. [pmid: 16887941].
Cummins SK, Jackson RJ. The built environment and children’s health. Pediatr Clin N Am. 2001;48:1241-52.
Daley WR, Smith A, Paz-Argandona E, Malilay J, McGeehin M. An outbreak of carbon monoxide poisoning after a major ice storm in Maine. J Emerg Med. 2000;18(1):87-93. [pmid: 10645845].
Desor JA. Toward a psychological theory of crowding. J Pers Soc Psychol. 1972;21:79-83.
Dunn JR, Walker JD, Graham J, Weiss CB. Gender differences in the relationship between housing, socioeconomic status, and self-reported health status. Rev Environ Health. 2004;19(3–4):177-95. [pmid: 15742670].
Ernst A, Zibrak JD. Carbon monoxide poisoning. N Engl J Med. 1998;339:1603-8. [pmid: 9828249].
Evans GW, Lepore SJ, Schroeder A. The role of interior design elements in human responses to crowding. J Pers Soc Psychol. 1996;70:41-6.
Evans GW, Lepore SJ, Allen KM. Cross-cultural differences in tolerance for crowding: fact or fiction?. J Pers Soc Psychol. 2000;79:204-10. [pmid: 10948974].
Evans GW, Saegert S, Harris R. Residential density and psychological health among children in low-income families. Environ Behav. 2001;33:165-80.
Evans GW, Marcynyszyn LA. Environmental justice, cumulative environmental risk and health among low- and middle-income children in upstate New York. Am J Public Health. 2004;96:1942-4. [pmid: 15514234].
Foarde KK. 1998. Proper use of biocides in HVAC systems. National Air Duct Cleaners 9th Annual Meeting and Exposition, 1998. Research Triangle Park, NC. Research Triangle Institute.
Field RW, Steck DJ, Smith BJ, Brus CP, Fisher EL, Neuberger JS, et al. Residential radon gas exposure and lung cancer: the Iowa radon lung cancer study. Am J Epidemiol. 2000;151:1091-102. [pmid: 10873134].
Flores G, Tomany-Korman SC, Olson L. Does disadvantage start at home? Racial and ethnic disparities in health-related early childhood home routines and safety practices. Arch Pediatr Adolesc Med. 2005;159:158-65. [pmid: 15699310].
Frumkin H, Frank L, Jackson R. 2004. Urban sprawl and public health: designing, planning, and building for healthier communities. Washington, DC. Island Press.
Frumkin H, Samet JM. Radon. CA Cancer J Clin. 2001;51:337-44. [pmid: 11760568].
Gielen AC, Wilson MEH, Faden RR, Wissow L, Harvilchuck JD. In-home injury prevention practices for infants and toddlers: the role of parental beliefs, barriers, and housing quality. Health Educ Q. 1995;22:85-95. [pmid: 7721603].
Golden RN, Gaynes BN, Ekstrom RD, Hamer RM, Jacobsen FM, Suppes T, et al. The efficacy of light therapy in the treatment of mood disorders: a review and meta-analysis of the evidence. Am J Psychiatr. 2005;162:656-62. [pmid: 15800134].
Greer FR, Shannon M. Committee on Nutrition, Committee on Environmental Health. Infant methemoglobinemia: the role of dietary nitrate in food and water. Pediatrics. 2005;116(3):784-6. [pmid: 16140723].
Grosse SD, Matte TD, Schwartz J, Jackson RJ. Economic gains resulting from the reduction in children’s exposure to lead in the United States. Environ Health Perspect. 2002;110:563-9. [pmid: 12055046].
Hall JR. 2001. Burns, toxic gases, and other hazards associated with fires: deaths and injuries in fire and non-fire situations. Quincy, MA. National Fire Protection Association.
Hannon L, Shai D. The truly disadvantaged and the structural covariates of fire death rates. Soc Sci J. 2003;40(1):129-36.
Hendershot G. 2004. Building design is leading barrier to community participation. Washington, DC. National Organization on Disability. Available at http://www.nod.org. accessed 2007 August 14.
Institute of Medicine. 2000. Clearing the air: asthma and indoor air exposures. Washington, DC. The National Academies Press.
Institute of Medicine. 2004. Damp indoor spaces and health. Washington, DC. The National Academies Press.
Institute of Medicine. 2005. Ethical considerations for research on housing-related health hazards involving children. Washington, DC. The National Academies Press.
Istre GR, McCoy MA, Osborn L, Barnard JJ, Bolten A. Deaths and injuries from house fires. N Engl J Med. 2001;344:1911-6. [pmid: 11419429].
Jacobs DE. A qualitative review of housing hazard identification protocols in the United States. Environ Res. 2006;102:13-21. [pmid: 16448643].
Jacobs DE, Clickner RP, Zhou JY, Viet SM, Marker DA, Rogers JW, et al. The prevalence of lead-based paint hazards in U.S. housing. Environ Health Perspect. 2002;110:A599-A606. [pmid: 12361941].
Jacobs DE, Kelly T, Sobolewski J. Linking public health, housing and indoor environmental policy: successes and challenges at the local and federal agencies in the United States. Environ Health Perspect. 2007;115:976-82. [pmid: 17589610].
Jargowsky PA. 1997. Poverty and place: ghettos, barrios, and the American city. New York. Russell Sage Foundation.
Joint Center for Housing Studies of Harvard University. 2004. The state of the nation’s housing: 2004. Cambridge, MA. President and Fellows of Harvard College. Available at http://www.jchs.harvard.edu/publications/markets/son2004.pdf. accessed 2007 August 17.
Joint Center for Housing Studies of Harvard University. 2008. The state of the nation’s housing: 2008. Cambridge, MA. President and Fellows of Harvard College. Available at http://www.jchs.harvard.edu/publications/markets/son2008.pdf. accessed 2008 June 29.
Jones RL, Homa DM, Meyer PA, Brody DJ, Caldwell KL, Pirkle JL, et al. Trends in blood lead levels and blood lead testing among U.S. children aged 1 to 5 years: 1998–2004. Pediatrics. 2009;123(3):e376-85. [pmid: 19254973].
Karter MJ. 2007. Fire loss in the United States during 2006. Quincy, MA. National Fire Protection Association.
Kattan M, Stearns SC, Crain EF, Stout JW, Gergen PJ, Evans R 3rd, et al. Cost effectiveness of home-based environmental intervention for inner-city children with asthma. J Allergy Clin Immunol. 2005;116:1058-63. [pmid: 16275376].
Katz LF, Kling JR, Liebman JB. Moving to opportunity in Boston: early results of a randomized mobility experiment. Q J Econ. 2001;116(2):607-54.
Klitzman S, Caravanos J, Belanoff C, Rothenberg L. A multihazard, multistrategy approach to home remediation: results of a pilot study. Environ Res. 2005;99:294-306. [pmid: 16154560].
Krieger J, Higgins DL. Housing and health: time again for public health action. Am J Public Health. 2002;92:758-68. [pmid: 11988443].
Krieger JW, Takaro TK, Song L, Weaver M. The Seattle-King County healthy homes project: a randomized controlled trial of a community health worker intervention to decrease exposure to indoor asthma triggers. Am J Public Health. 2005;95:642-59.
Kripke KF. Light treatment for nonseasonal depression: speed, efficacy and combined treatment. J Affec Disord. 1998;49:109-17.
Leaver CA, Bargh G, Dunn JR, Hwang SW. The effects of housing status on health-related outcomes in people living with HIV: a systematic review of the literature. AIDS Behav. 2007;11(suppl 6):85-100. [pmid: 17682940].
Lepore SJ, Evans GW, Schneider ML. Role of control and social support in explaining the stress of hassles and crowding. Environ Behav. 1992;24:795-811.
Leventhal T, Brooks-Gunn J. Moving to opportunity: An experimental study of neighborhood effects on mental health. Am J Public Health. 2003;93(9):1576-82. [pmid: 12948983].
Levin R, Brown MJ, Kashtock ME, Jacobs DE, Whelan EA, Rodman J. Children’s lead exposures in the United States, 2008: implications for primary lead poisoning prevention strategies. Environ Health Perspect. 2008;116(10):1285-93. [pmid: 18941567].
Lu C, Knutson DE, Fisker-Andersen J, Fenske RA. Biological monitoring survey of organophosphorous pesticide exposure among preschool children in the Seattle metropolitan area. Environ Health Perspect. 2001;109:299-303. [pmid: 11333193].
MacKay M. Playground injuries. Inj Prev. 2003;9(3):194-6. [pmid: 12966004].
Marshall SW, Runyan CW, Yang J, Coyne-Beasley T, Waller AE, Johnson RM, et al. Prevalence of selected risk and protective factors for falls in the home. Am J Prev Med. 2005;28:95-101. [pmid: 15626563].
Matsui EC, Wood RA, Rand C, Kanchanaraksa S, Swartz L, Curtin-Brosnan J, et al. Cockroach allergen exposure and sensitization in suburban middle-class children with asthma. J Allerg Clin Immunol. 2003;112:87-92.
Matte TD, Jacobs DE. Housing and health—current issues and implications for research and programs. J Urban Health. 2000;77:7-25. [pmid: 10741839].
McDonald J. 2002. Nursery product-related deaths and injuries to children under age 5. Washington, DC. U.S. Consumer Product Safety Commission. Available at http://www.cpsc.gov/LIBRARY/nursery05.pdf. accessed 2009 April 16.
McDonald EM, Gielen AC. Gielen AC, Sleet DA, DiClemente R, editors. House fires and other intentional home injuries. Injury and violence prevention: behavioral science theories, methods and applications. San Francisco, CA. Jossey-Bass. 2006:274-96.
McDonald EM, Girasek DC, Gielen AC. Liller KD, editor. Home injuries. Injury prevention for children and adolescents: research, practice, and advocacy. Washington, DC. American Public Health Association. 2006:125-30.
McLoughlin E, Marchone M, Hanger L, German PS, Baker SP. Smoke detector legislation: its effect on owner-occupied homes. Am J Public Health. 1985;75(8):858-62. [pmid: 4025645].
Messner M Shaw S Regli S Rotert K Blank V Soller J 2006 An approach for developing a national estimate of waterborne disease due to drinking water and a national estimate model application J Water Health 4 suppl 2 201–40.)16895092
Miller M, Azrael D, Hemenway D, Vriniotis M. Firearm storage practices and rates of unintentional firearm deaths in the United States. Accid Anal Prev. 2005;37:661-7. [pmid: 15949457].
Moritz AR, Henriques FC. Studies of thermal injury: the relative importance of time and surface temperature in the causation of cutaneous burns. Am J Pathol. 1947;23:695-720. [pmid: 19970955].
Mudarri D, Fisk WJ. Public health and economic impact of dampness and mold. Indoor Air. 2007;17:226-35. [pmid: 17542835].
Nagaraja J, Menkedick J, Phelan KJ, Ashley P, Zhang X, Lanphear BP. Deaths from residential injuries in US children and adolescents, 1985–1997. Pediatrics. 2005;116:454-61. [pmid: 16061603].
National Alliance to End Homelessness. 2007. Policy guide. Washington, DC. National Alliance to End Homelessness.
National Center for Healthy Housing. 2008. Boston One Touch: action steps for healthier and greener homes for Boston families. Columbia, MD. National Center for Healthy Housing.
National Institute of Building Sciences. 2005. IEQ Indoor environmental quality. Washington, DC. National Institute of Building Sciences. Available at http://ieq.nibs.org/ieq_project.pdf. accessed 2009 February 18.
Naughton MP, Henderson A, Mirabellin MC, Kaiser R, Wilhelm JL, Kieszak SM, et al. Heat-related mortality during a 1999 heat wave in Chicago. Am J Prev Med. 2002;22:221-7. [pmid: 11988377].
New York City Department of Health. 2000. Guidelines on assessment and remediation of fungi in indoor environments. New York City Bureau of Environmental and Occupational Disease Epidemiology.
Orr L, Feins JD, Jacob R, Beecroft E. 2003. Moving to opportunity: interim impacts evaluation. Washington, DC. U.S. Department of Housing and Urban Development. Available at http://www.huduser.org/Publications/pdf/MTOFullReport.pdf. accessed 2009 April 16.
Passchier-Vermeer W, Passchier WF. Noise exposure and public health. Environ Health Perspect. 2000;108(suppl 1):123-31. [pmid: 10698728].
Pirkle JL, Bernert JT, Caudill SP, Sosnoff CS, Pechacek TF. Trends in the exposure of nonsmokers in the U.S. population to secondhand smoke: 1988–2002. Environ Health Perspect. 2006;114:853-8. [pmid: 16759984].
Proscio T. 2004. Healthy housing, healthy families: toward a national agenda for affordable healthy homes. Columbia, MD. National Center for Healthy Housing.
Quan L, Bennett EE, Branche CM. Doll LS, Bonzo SE, Sleet DA, Mercy JA, Haas EN, editors. Interventions to prevent drowning. Handbook of injury and violence prevention. New York. Springer. 2007:81-96.
Raub JA, Mathieu-Nolf M, Hampson NB. Carbon monoxide poisoning—a public health perspective. Toxicology. 2000;145:1-14. [pmid: 10771127].
Rauchschwalbe R, Mann NC. Pediatric window-cord strangulations in the United States, 1981–1995. JAMA. 1997;277(21):1696-8. [pmid: 9169896].
Regoeczi WC. When context matters: a multilevel analysis of household and neighborhood crowding on aggression and withdrawal. J Environ Psychol. 2003;23:457-70.
Rice D, Barone S Jr. Critical periods of vulnerability for the developing nervous system: evidence from humans and animal models. Environ Health Perspect. 2000;108(suppl 3):511-33. [pmid: 10852851].
Rog DL, McCombs-Thornton DL, Gilbert-Mongelli AM, Brito MC, Holupka DS. Implementation of the homeless families program: 2. Characteristics, strengths and needs of participant families. Am J Orthopsychiatry. 1995;64:514-28. [pmid: 8561185].
Rubenstein LZ, Stevens JA, Scott V. Doll LS, Bonzo SE, Sleet DA, Mercy JA, Haas EN, editors. Interventions to prevent falls among older adults. Handbook of injury and violence prevention. New York. Springer. 2007:37-53.
Runyan CW, Casteel C, Perkis D, Black C, Marshall SW, Johnson RM, et al. Unintentional injuries in the home in the United States, part I: mortality. Am J Prev Med. 2005a;28:73-9. [pmid: 15626560].
Runyan CW, Perkis D, Marshall SW, Johnson RM, Coyne-Beasley T, Waller AE, et al. Unintentional injuries in the home in the United States, part II: morbidity. Am J Prev Med. 2005b;28:80-7. [pmid: 15626561].
Salam MT, Li Y-F, Langholz B, Gilliland FD. Children’s Health Study. Early-life environmental risk factors for asthma: findings from the Children’s Health Study. Environ Health Perspect. 2004;112:760-765. [pmid: 15121522].
Saluja G, Brenner RA, Trumble AC, Smith GS, Schroeder T, Cox C. Swimming pool drownings among US residents aged 5–24 years: understanding racial/ethnic disparities. Am J Public Health. 2006;96(4):728-33. [pmid: 16507730].
Savinar J. The effect of ceiling height on personal space. Man-Environment Systems. 1975;5:321-4.
Sharfstein J, Sandel M, editors. 1998. Not safe at home: how America’s housing crisis threatens the health of its children. Boston. Boston Medical Center.
Shenassa ED, Stubbendick A, Brown MJ. Social disparities in housing and related pediatric injury: a multilevel study. Am J Public Health. 2004;94(4):633-9. [pmid: 15054017].
Shenassa ED, Daskalakis D, Liebhaber A, Braubach M, Brown MJ. Dampness and mold in the home and depression: an examination of mold-related illness and perceived control of one’s home as possible depression pathways. Am J Public Health. 2007;97:1893-9. [pmid: 17761567].
Shinn M, Weitzman BC, Stojanovic D, Knickman JR, Jimenez I, Duchon L, et al. Predictors of homelessness among families in New York City: from shelter request to housing stability. Am J Public Health. 1998;88:1651-7. [pmid: 9807531].
Smith CL. 1993. Smoke detector operability survey—report on findings. Bethesda, MD. U.S. Consumer Product Safety Commission.
Staunton CE, Frumkin H, Dannenberg AL. Doll LS, Bonzo SE, Sleet DA, Mercy JA, Haas EN, editors. Changing the built environment to prevent injury. Handbook of injury and violence prevention. New York. Springer. 2007:257-76.
Stojanovic D, Weitzman BC, Shinn M, Labay LE, Williams NP. Tracing the path out of homelessness: the housing patterns of families after exiting shelter. J Commun Psychol. 1999;27:199-208.
Thompson NJ, Waterman MB, Sleet DA. Using behavioral science to improve fire escape behaviors in response to a smoke alarm. J Burn Care Rehabil. 2004;25(2):179-88. [pmid: 15091145].
Ulrich RS. View through a window may influence recovery from surgery. Science. 1984;224:420-1. [pmid: 6143402].
U.S. Census Bureau. 2006. Current housing reports, series H150/05, American Housing Survey for the United States: 2005. Washington, DC. U.S. Government Printing Office.
U.S. Consumer Product Safety Commission. undated a. National Electronic Injury Surveillance System (NEISS) on-line. Washington, DC. U.S. Consumer Product Safety Commission. Available at http://www.cpsc.gov/LIBRARY/neiss.html. accessed 2008 July 21.
U.S. Consumer Product Safety Commission. undated b. How to plan for the unexpected: preventing child drownings. Washington, DC. U.S. Consumer Product Safety Commission. Publication no. 359. Available at http://www.cpsc.gov/cpscpub/pubs/359.pdf.
U.S. Consumer Product Safety Commission. undated c. Children can strangle in window covering cords. Washington, DC. U.S. Consumer Product Safety Commission. Available at http://www.cpsc.gov/CPSCPUB/PUBS/cords.html. accessed 2008 July 22.
U.S. Department of Energy. 2006. 2006 buildings energy data book. Washington, DC. U.S. Government Printing Office.
U.S. Department of Health and Human Services. 2005a. Report of the Surgeon General’s Workshop on Healthy Indoor Environment, January 12–13, 2005. Washington, DC. U.S. Department of Health and Human Services. Available at http://www.surgeongeneral.gov/topics/indoorenv/. accessed 2007 August 17.
U.S. Department of Health and Human Services. 2005b. Surgeon General releases national health advisory on radon. Washington, DC. U.S. Department of Health and Human Services. Available at http://www.surgeongeneral.gov/pressreleases/sg01132005.html. accessed 2007 August 17.
U.S. Department of Health and Human Services. 2006. The health consequences of involuntary exposure to tobacco smoke: a report of the Surgeon General. Atlanta, GA. Centers for Disease Control and Prevention.
U.S. Department of Housing and Urban Development. 1995. Guidelines for the evaluation and control of lead-based paint hazards in housing. Washington, DC. U.S. Department of Housing and Urban Development. Available at http://www.hud.gov/offices/lead/lbp/hudguidelines. accessed 2007 August 17.
U.S. Department of Housing and Urban Development. 2000. Strategic plan FY2000–FY2006. Washington, DC. U.S. Department of Housing and Urban Development.
U.S. Department of Housing and Urban Development. 2007. Affordable housing needs 2005: report to Congress. Washington, DC. U.S. Department of Housing and Urban Development. Available at: http://www.huduser.org/publications/affhsg/affhsgneeds.html. accessed 2008 August 5.
U.S. Environmental Protection Agency. 1998. Children’s vulnerability to toxic substances in the environment. Washington, DC. U.S. Environmental Protection Agency.
U.S. Environmental Protection Agency. 2001. Mold remediation in schools and commercial buildings. EPA 402-K-01-001. Washington, DC. U.S. Environmental Protection Agency. Available at http://www.epa.gov/mold/mold_remediation.html. accessed 2008 July 30.
U.S. Environmental Protection Agency. 2003. EPA Assessment of risks from radon in homes. EPA 402-R-03-003. Washington, DC. U.S. Environmental Protection Agency. Available at http://www.epa.gov/radon/pdfs/402-r-03-003.pdf. accessed 2008 June 9.
U.S. Environmental Protection Agency. 2004. Pesticides industry sales and usage: 2000 and 2001 market estimates. Washington, DC. U.S. Environmental Protection Agency. Available at http://epa.gov/oppbead1/pestsales/01pestsales/market_estimates2001.pdf. accessed 2008 June 12.
U.S. Environmental Protection Agency. 2007. Important exposure factors for children: an analysis of laboratory and observational field data characterizing cumulative exposure to pesticides. EPA 600-R-07-013. Washington, DC. U.S. Environmental Protection Agency. Available at http://www.epa.gov/nerl/research/data/exposure-factors.pdf. accessed 2008 August 1.
U.S. Environmental Protection Agency. undated a. Radon health risks. Washington, DC. U.S. Environmental Protection Agency. Available at http://www.epa.gov/radon/healthrisks.html. accessed 2007 July 26.
U.S. Environmental Protection Agency. undated b. Map of radon zones. Washington, DC. U.S. Environmental Protection Agency. Available at http://www.epa.gov/radon/zonemap.html. accessed 2008 June 9.
U.S. Environmental Protection Agency. undated c. Private drinking water wells. Washington, DC. U.S. Environmental Protection Agency. Available at http://www.epa.gov/safewater/privatewells/index2.html. accessed 2007 July 26.
U.S. Environmental Protection Agency. undated d. Household hazardous waste. Washington, DC. U.S. Environmental Protection Agency. Available at http://www.epa.gov/garbage/hhw.html. accessed 2008 August 15.
U.S. Fire Administration. 2006. Fire and the older adult. FA-300. Washington, DC. U.S. Government Printing Office. Available at: http://www.usfa.dhs.gov/downloads/pdf/publications/fa-300.pdf. accessed 2009 April 16.
von Hoffman A. 1998. The origins of American housing reform. Providence, RI. Harvard University Joint Center for Housing Studies.
Warda LJ, Ballesteros MF. Doll LS, Bonzo SE, Sleet DA, Mercy JA, Haas EN, editors. Residential fire injury prevention. Handbook of injury and violence prevention. New York. Springer. 2007:97-115.
Warda L, Tenenbein M, Moffatt MEK. House fire injury prevention update. Part I: a review of risk factors for fatal and non-fatal house fire injury. Inj Prev. 1999;5:145-50. [pmid: 10385837].
Washington State Department of Health. 1998. 1997 annual report, Pesticide Incident Reporting and Tracking Review Panel. Olympia, WA. Washington State Department of Health.
Watson WA, Litovitz TL, Klein-Schwartz W, Rodgers GC Jr, Youniss J, Reid N, et al. 2003 Annual report of the American Association of Poison Control Centers Toxic Exposures Surveillance System. Am J Emerg Med. 2004;22(5):335-404. [pmid: 15490384].
Wells NM. At home with nature: effects of “greenness” on children’s cognitive functioning. Environ Behav. 2000;32:775-95.
Williams MK, Barr DB, Camann DE, Cruz LA, Carlton EJ, Borjas M, et al. An intervention to reduce residential insecticide exposure during pregnancy among an inner city cohort. Environ Health Perspect. 2006;114:1684-9. [pmid: 17107853].
World Meteorological Organization. undated. Natural hazards. Available at http://www.wmo.int/pages/themes/hazards/index_en.html. accessed 2009 April 16.
Zaloshnja E, Miller TR, Lawrence BA, Romano E. The costs of unintentional home injuries. Am J Prev Med. 2005;28(1):88-94. [pmid: 15626562].