# Glossary

Affordable housing: The requirement that the cost of housing, both at initial occupancy and throughout the expected life of the tenancy, is within the financial reach of the target market for such housing, typically low-income families. An accepted guideline is that housing will cost no more than 30% of annual income.
Age in place: The ability to continue to live in one’s current residence as one ages, rather than going to live with relatives, especially children, or being placed in a nursing home. The ability for residents to “age in place” is largely contingent upon adapting housing to meet the specialized needs of the elderly.
Housing: A structure that serves as a dwelling for one or more persons or families. In this document, housing includes the structure itself, as well as the land and any additional structures within the property-line boundaries. Homes must be of market-competitive quality that can blend in to its neighborhood; this explicitly excludes substandard locations and configurations.
Green building: The practice of reducing building impacts on human health and the environment through better siting, design, construction, operation, maintenance, and removal of building structures and by increasing the efficiency with which buildings and their sites use and harvest energy, water, and materials.
Health literacy: The ability of an individual to access, understand, and use health-related information and services to make appropriate health decisions.
Holistic: Emphasizing the importance of the whole and the interdependence of its parts. From a housing/human health perspective, this entails considering the interactions among the housing structure, occupant behaviors, and health in an integrated manner.
Multifamily dwelling: A building designed to accommodate two or more unrelated households within the same structure. Such structures may require special zoning. Multifamily dwellings include garden apartments, mid-rise and high-rise apartment buildings, and residential condominiums.
Universal design: An approach to the design and construction of housing and environments to be usable by everyone to the greatest extent possible regardless of age, ability, or circumstance. Universal design benefits everyone by accommodating everyone, including those with limitations.
Visitability: Construction practices that encourage all homes to offer specific features that make it easier for people—particularly those who develop mobility impairment, the elderly, and persons with disabilities—to live in and visit. A companion to universal design.