# Foreword from the Acting Surgeon General, U.S. Department of Health and Human Services

Nightingale understood that health status is directly related to the home and consistently stressed that housing can cause or can contribute to numerous illnesses and injuries. In the United States today the leading preventable causes of death, disease, and disability are asthma, lead poisoning, deaths in house fires, falls on stairs and from windows, burns and scald injuries, and drowning in bathtubs and pools. Although residents of poorly maintained homes are at increased risk for injury and illness, no population group is immune to illness or injury occurring in houses. Design features of the house and how a house is linked to the surrounding neighborhood also affects health (Krieger and Higgins 2002).

A healthy home is sited, designed, built, renovated, and maintained in ways that support the health of residents. Specific features that constitute healthy housing include structural and safety aspects of the home (i.e., how the home is designed, constructed, and maintained; its physical characteristics; and the presence or absence of safety devices), quality of indoor air and water, and the presence or absence of chemicals. Individual resident behavior, such as installing and maintaining smoke alarms, implementing smoke-free rules, and controlling or eliminating hazards such as lead paint and radon gas also are important aspects of healthy and safe home environments. The surrounding neighborhood and community are also important aspects of healthy homes. Finally, homelessness, which is the worst case of lack of access to healthy housing, has dire health consequences.

I have issued The Surgeon General’s Call to Action To Promote Healthy Homes to focus attention on the public health impact of housing and to begin a national dialogue on how we can promote healthy homes in the United States. This Call to Action presents an overview of issues that contribute to our nation’s unhealthy housing. It also urges a dynamic and coordinated effort to improve housing factors that affect health and describes features that make a house and its surrounding property healthy. A series of mutually supportive and mutually necessary coordinated actions are outlined in this document. They call on people from many walks of life to join in a discussion about healthy homes issues; to make informed, shared, and compassionate decisions; and to develop imaginative and realistic solutions that will help ensure that safe, healthy, affordable, and accessible homes are available to everyone in the United States.

Steven K. Galson, M.D., M.P.H.

RADM, USPHS, Acting Surgeon General