# Conclusions

With this Call to Action To Promote Healthy Homes, the Surgeon General emphasizes that health must begin at home. To improve the nation’s overall health, we must improve the health of the nation’s homes and ensure that safe, healthy, affordable, accessible, and environmentally friendly homes are available to everyone in the United States. This is no small task; it will require dedication, ingenuity, skill, and the concerted effort on the parts of many people in many sectors. Several key participants have been identified and are enthusiastically engaged. The actions outlined in this document are the next steps. Strengthening and widening these efforts is an urgent matter. Ensuring that the nation’s homes are safe, healthy, affordable, accessible, and environmentally friendly will have a direct, immediate, and measurable affect on the health of the nation.