# Ensuring Healthy Homes: Taking Action for the Future

This Call to Action builds on the Surgeon General’s report on healthy indoor environment (U.S. Department of Health and Human Services 2005a), the research presented at the seventh National Environmental Public Health Conference sponsored by CDC in December of 2006, and the thoughtful contributions of subject-matter experts from a number of federal agencies (see Acknowledgements). These goals are not isolated; rather, they are highly integrated components of an overall approach to promote healthy homes in the United States. They call on people from many walks of life to join in a discussion about healthy homes issues; to make informed, shared, and compassionate decisions; and to develop imaginative and realistic solutions that will help ensure that a safe, healthy, affordable and accessible home is available to everyone in the United States. This section describes the rationale that supports each of the four goals, the challenges to achieving these goals, and the actions that will help to achieve them.

## Goal 1: Ensuring Healthy, Safe, Affordable, and Accessible Homes

### Rationale

People in the United States spend 50% or more of every day inside their homes (Centers for Disease Control and Prevention and U.S. Department of Housing and Urban Development 2006). A healthy, safe, affordable, and accessible home supports residents’ fundamental physical and psychological needs and protects them from illness and injury.

### Challenges

The risk for serious injury, toxic exposures, and illness is increased among those who are least able to find and afford healthy homes. Steps must be taken to eliminate disparities in housing conditions arising from social and economic disadvantage so that people in the United States from all walks of life, ages, and racial and ethnic backgrounds will share the opportunity to have homes that promote and protect health.

### Actions

For some residential hazards, evidence-based interventions already exist to reduce exposures that cause disease and to prevent injuries. Now these interventions must be made available to all who need them. All levels of society, from single persons and families to government organizations, can begin to implement strategies that will make safe, healthy, affordable, and accessible homes a central component of the nation’s public health architecture. Home modifications should be attractive, appropriate for home setting, easy to implement, straightforward to use, affordable, and effective.

#### For Individuals, Families, Property Owners, and Maintenance Workers

Persons, families, and property owners can take action to make their homes healthier and more environmentally friendly by improving air quality, safely using various household products, properly using safety devices, adequately supervising children, and abating specific toxic chemicals. Examples of these actions include the following:

- Install, maintain, and consistently use safety devices (e.g., smoke alarms; carbon monoxide alarms; stair gates in homes with young children; grab bars in bathrooms; adequate outside lighting; locks on cabinets used to store medicines, cleaning solutions, automotive supplies, firearms and ammunition, pool chemicals, and pesticides; four-sided isolation fencing with self-closing, self-latching doors around pools).
- Complete a home fall-prevention checklist for homes with older adults (see http://www.cdc.gov/ncipc/duip/fallsmaterial.htm#BRochures).
- Prepare and practice an emergency fire escape plan (see http://www.firesafety.gov/citizens/escape/index.shtm).
- Prepare shelter-in-place and evacuation plans for weather and other disaster situations (visit http://www.redcross.org/preparedness/cdc_english/home.asp for more information).
- Set water temperature in your home at 120°F.
- Routinely check electrical appliances and wiring; replace all worn, old, or damaged appliance cords; do not overload extension cords or wall sockets.
- Check gas appliances, fireplaces, chimneys, and furnaces yearly and change furnace and air conditioning filters regularly. Never use the oven, stove, charcoal burner, or any unvented combustible heat source to heat the house.
- Do not smoke; enforce smoke-free rules in the home. If you do smoke, do not smoke indoors or around children. For support in quitting smoking, including free quit coaching, a free quit plan, free educational materials, and referrals to local resources, call 1-800-QUIT-NOW (1-800-784-8669) or visit http://www.smokefree.gov.
- Complete a playground safety checklist if you have playground equipment in your yard (see http://www.cpsc.gov/cpscpub/pubs/pg1.pdf).
- Replace balcony railings spaced greater than 4 inches apart.
- Review the EPA listing of safer cleaning products (see http://wwww.epa.gov/dfe/pubs/projects/formulat/formpartc.htm#consumerclean) and select the safest products for the job.
- Keep toxic chemicals, including cleaning products and pesticides, away from children. Choose products with poison-prevention packaging.
- Read product labels and follow directions for use and disposal.
- Consider integrated pest management, including natural, biological, and chemical methods with the least impact on health and the environment.
- Control moisture in the home by sealing cracks, directing downspouts away from the house, installing drains near water heaters and washing machines, and properly installing window air conditioner units.
- Test houses for radon and install a mitigation system if the test result is 4 pCi/L or higher.
- Include radon mitigation systems or radon-resistant construction— or both—in new home construction located in the midwestern and eastern United States.
- Test houses occupied by children less than 6 years of age for lead and control or eliminate lead hazards.
- Make sure that infants sleep on their backs on firm sleeping surfaces.
- Use lead-safe work practices when renovating houses built before 1978.
- Contact the local or state health department for assistance remediating lead or radon hazards.
- Leave asbestos material in good condition alone. If the material is damaged or you plan to repair or renovate parts of your home that may contain asbestos material, hire a professional.
- Consider green, environmentally friendly options when selecting home sites, materials, and appliances; when building or renovating; and when using natural resources such as water and energy, like those suggested on the EPA’s Green Building Web site (http://www.epa.gov/greenbuilding).

#### For Community- and Faith-based Organizations

Community- and faith-based organizations have a critical role in educating at-risk populations about the connection between homes and health and in identifying and addressing home deficiencies. Examples of actions these organizations can take include the following:

- Support adoption of healthy, safe, accessible, affordable, and environmentally friendly homes.
- Provide home-visiting programs with information on supportive housing for people with mental health problems.
- Inform older adults; people with disabilities; and housing and health care professionals about eligibility and coverage in existing home modification services and products (e.g., Medicare, Medicaid, Community Development Block Grants).
- Mediate disputes between tenants and property owners to help stabilize rental properties and prevent evictions.
- Adopt “rapid exit” policies in homeless shelters that ensure that families are quickly released and stay housed thereafter.

#### For Health Care Providers and Home-Visiting Programs

Health care providers and home-visiting programs can promote a more comprehensive and coordinated approach by incorporating healthy housing solutions into their protocols. Examples of these actions include the following:

- Cross-train home-visit staff to identify and address home deficiencies and assist families living in unstable or unsafe home situations or who are at risk for losing their homes.
- Cross-train home-visit staff to assist elderly, individuals with disabilities and their caregivers, and low-income families with fall-prevention measures and the installation and maintenance of smoke alarms, carbon monoxide detectors, and other safety devices.
- Identify and adopt appropriate interventions that have proven successful in nonresidential settings, such as ladder safety standards and training and safety programs designed to prevent hand injury or toxic exposure.

#### For Lenders, Developers, and Home Builders and Inspectors

Builders, developers, lenders, and mortgage holders are essential to development of a safe, healthy, affordable, and accessible home portfolio. Examples of actions these groups can take include the following:

- Train builders in healthy home construction and building management principles.
- Consider health and safety factors when selecting building sites, construction materials, and building systems.
- Apply smart-growth principles to groups of homes and larger communities.
- Develop lending instruments that consider the financial benefits of healthy homes.
- Dedicate a portion of the Community Reinvestment Act funding to support development of safe and healthy homes.
- Train home inspectors to identify and report on a range of safety and health hazards.

#### For Government

Communities have a variety of policies and laws at their disposal for creating and maintaining healthy homes, including voluntary efforts, regulatory authority, and formal relationships between homes and health professionals. Decisions made at the local, state, and federal levels also can help create homes that are affordable and that improve people’s health. Examples of actions government can take include the following:

- Develop and improve upon response plans for extreme weather events (e.g., when use of generators, candles, fireplaces, chain saws, and grills increases) that include education and interventions to prevent dangerous exposures and injuries and incorporate these plans into the health and housing programs in their jurisdictions.
- Enforce housing and sanitary code requirements.
- Conduct regular and comprehensive inspections of subsidized properties and require that these units meet basic safety and sanitary requirements.
- Use housing subsidies to promote mixed-income neighborhoods.
- Use market-based incentives to provide economic compensation to promote healthy homes (e.g., compensating property owners for their costs related to healthy and safe home modifications that benefit society at large).
- Model incentives for healthy homes on existing incentives for energy-efficient products.
- Develop data-sharing and consistent criteria across social service and housing agencies for measuring barriers to permanent homes.
- Emphasize prevention of homelessness and target effectively those at highest risk.
- Integrate housing-related strategies including providing a single entry point for determination of eligibility for services that is co-located with intake centers for other social and aging services.
- Work together across agencies and sectors to provide guidance and technical assistance to support safe, healthy, and environmentally friendly housing options.

## Goal 2: Increase Public Awareness and Promote Health Literacy

### Rationale

There is a need to improve the public’s understanding of the connection between housing and health. Health literacy, including an understanding of the concepts and terms related to healthy homes, helps people take actions that foster healthy and safe homes. Stakeholders, including educators, community-based organizations, and others have key roles in improving housing-health literacy.

### Challenges

Rental property owners, tenants, and single-family homeowners should receive information and tools that could help them make homes safer, healthier, and more environmentally friendly. Because many of these practices must be adopted and maintained by the residents themselves, educational efforts must both provide information and encourage behavior modifications. Educational materials must include guidance about specific steps people can take to reduce health hazards in their homes and strongly promote the benefits of taking such actions. Great care must be taken to develop messages that are inclusive, culturally sensitive, and linguistically appropriate to meet the needs of the socially, economically, and ethnically diverse U.S. population. A broad range of stakeholders should be engaged in crafting these messages.

### Actions

#### For Educators

Improving healthy homes requires the talents and skills of traditional and nontraditional health and housing partners. Each member of a multidisciplinary healthy homes workforce must understand basic housing-related health issues. This knowledge base will arm team members with a common, science-based framework for identifying, developing, and implementing healthy housing practices. Examples of actions educators can take include the following:

- Incorporate healthy and environmentally friendly housing education into training programs for public health, environmental health, business administration, and housing professionals; urban planners; architects; and engineers as well as construction, maintenance, pest control, and weatherization experts.
- Partner with community-based organizations to provide health professional trainees—particularly in nursing education and primary care residency programs—with an enhanced understanding of how housing influences health.
- Use the model healthy housing education programs sponsored by CDC, HUD, and the U.S. Department of Agriculture for training.
- Consider establishing healthy homes fellowship programs to provide on-site training for emerging leaders in the field.

#### For Community- and Faith-based Organizations

Community- and faith-based organizations and housing advocacy groups must work together to address both residential needs and economic development, to promote greater knowledge about the ways in which housing affects health issues, and to support leaders’ efforts to make informed, evidence-based, and compassionate housing decisions. Examples of actions these groups can take include the following:

- Collaborate with government agencies and academic institutions to ensure that educational materials address community priorities and are appropriate to meet the community’s educational needs.
- Develop public awareness campaigns that promote healthy, safe, affordable, accessible, and environmentally friendly homes.
- Promote healthy and safe home modifications and repairs.

## Goal 3: Conduct Healthy Homes Research

### Rationale

Although in the last decade research demonstrating the link between specific housing conditions and health has matured, significant knowledge gaps remain. Addressing these gaps will require research that links housing conditions with specific health outcomes while accounting for personal, home unit, neighborhood, and community-level factors and the impact of disparate access to safe, healthy, affordable, and accessible homes. Research is also necessary to evaluate the effectiveness of comprehensive housing improvements, regulatory policies, and voluntary initiatives. Unless healthy housing is carefully studied in methodologically appropriate ways, the risk remains that families, property owners, and government agencies responsible for providing housing assistance will undertake expensive but ineffective interventions. Progress toward promoting healthy homes also depends on demonstrating that healthy homes is feasible, cost-efficient, and beneficial (Proscio 2004).

### Challenges

To advance public health actions that will have a significant impact on health, the nation needs a more holistic understanding of how housing affects people’s health (U.S. Department of Health and Human Services 2005a). Such research requires a broad approach involving many disciplines such as fire prevention, safety science, engineering, psychology, home design, epidemiology, exposure assessment, medicine, risk management, environmental science, and public policy science.

### Actions

#### For Government, Academic and Research Organizations and Scientists

Government agencies, other research organizations, and scientists should develop and support a portfolio of rigorous healthy homes research. They need to build interdisciplinary teams that are well versed in the conduct of community-based research and the use of sophisticated statistical techniques. Examples of actions these agencies and organizations can take include the following:

- Conduct research to identify additional housing factors that can harm, or promote and protect people’s health.
- Promote efforts to understand the causal sequences of events leading to specific injuries.
- Conduct research to advance our understanding of building practices and health and safety measures that improve resident health, such as the health consequences of energy-efficient buildings and smart technologies.
- Conduct research to determine safe levels of household chemicals for different types of housing and different subpopulations.
- Determine the impact of related, simultaneously implemented housing remediation on multiple health outcomes.
- Improve the design and statistical methods used to evaluate healthy homes intervention studies.
- Develop and implement a healthy homes monitoring and tracking system.
- Conduct studies that determine what proportion of illness and injury should be ascribed to unhealthy homes.
- Describe the biologic and other mechanisms that link the housing environment and mental health.
- Conduct research that identifies beneficial and detrimental behavioral responses to emergencies such as residential fires, mass-trauma events, and weather-related catastrophes.
- Quantify the costs of suboptimal housing and the costs and benefits of various strategies to make homes healthier.
- Test intervention strategies thought to improve health.
- Create academic programs to train future workers in the healthy homes field.

## Goal 4: Translate Research into Practice and Policy

### Rationale

To improve human health, research discoveries must be translated into practical applications. Both basic research, in which scientists study disease at a molecular or cellular level, and applied research, in which scientists study whether proposed interventions are effective, need to be brought to the reality of people’s lives.

### Challenges

The barriers between the scientific research community and the sectors of society that can benefit most directly from their work as well as the ever-increasing complexities involved in conducting scientific research make it difficult to move new knowledge from research to action in a timely way. The barriers and complexities also slow down information from the field that would help stimulate new research questions. Opportunities for communication between scientists and those in the field are few: limited rewards exist for scientists who pursue translation research and training opportunities are scarce. These challenges limit professional interest in the field and hamper the conduct of translation research at a time when it should be expanding.

### Actions

Once the best practices for prevention are identified, successfully translating them into actual practice should take two approaches: an approach that focuses on constructing and maintaining housing in ways that promote and protect health and an approach that addresses changing individual and community behaviors. Open collaboration among professionals involved in constructing and maintaining homes and scientists, government agencies, and housing advocacy organizations would ensure that each group has up-to-date information and access to resources.

#### For Government, Academic, and Research Organizations and Scientists

Government, academic, and research and other organizations that fund scientific research should ensure that activities to translate scientific findings into practice are supported in their sponsored research programs. Academic and research institutions and individual scientists should provide training and pursue opportunities in research translation; examples include the following:

- Develop and implement mechanisms for updating recommendations and communicating them to housing agencies and professionals involved in constructing and maintaining homes.
- Develop and implement mechanisms to accelerate the transfer of research findings into home-based health care and social services, housing programs, and other service-delivery systems.
- Use evidence-based interventions to develop or support a program to certify houses and homes-related consumer products as healthy and safe.
- Communicate research findings to the public, health care providers, and policy makers that clearly describe behaviors and actions that promote healthy homes.
- Communicate research findings through a broad range of media and products with the intention of widespread dissemination and adoption.