# The Need for Healthy Homes

The connection between housing and health is well established. As early as the mid-19^th^ century, physicians advocated for decent housing as a strategy to reduce death and illness among the poor (Krieger and Higgins 2002; von Hoffman 1998). The typhoid and tuberculosis experiences showed that basic sanitation, ventilation, reduced household crowding, and other improvements in housing made a powerful contribution to conquering these epidemics. Furthermore, improved sanitation through indoor plumbing, the creation of smooth and cleanable interior surfaces, and better food preservation and storage facilities in homes were clearly linked to other advances in public health. Many modern homes and building codes trace their ancestry to the public health responses to epidemics that occurred with the rapid industrialization and urbanization in Western countries over a hundred years ago. In the mid-20^th^ century, however, housing and health agencies became organizationally separated, resulting in a diminished focus on the prevention of housing-related disease and illness.

Recently, the public health community renewed its interest in promoting healthy homes. Multiple research studies have demonstrated improved health outcomes with policies targeting living conditions, especially homes. For example, lead poisoning prevention policies have greatly reduced childhood lead exposure in the United States (Centers for Disease Control and Prevention 2005a; Pirkle et al. 2006). Smoke alarm legislation has been demonstrated to increase working smoke alarm prevalence and to reduce fatal fires and fire deaths in a U.S. county (McLoughlin et al. 1985). These and many other successes highlight the health benefits of targeting interventions to reduce or eliminate health hazards in homes.

Many factors influence health and safety in homes, including structural and safety aspects of the home (i.e., how the home is designed, constructed, and maintained; its physical characteristics; and the presence or absence of safety devices); quality of indoor air; water quality; and chemicals; resident behavior; and the house’s immediate surroundings. Such factors support or detract from the health of those who live there. Some common hazards that affect health and safety include house fires caused by smoking or electrical hazards, carbon monoxide from poorly vented combustion, poor lighting, lack of handrails on stairs, open upper-story windows, improperly stored firearms and poisonous substances, moisture intrusion, radon gas, and inadequate supervision of children around bathtubs and pools. Many hazards potentially affect everyone, regardless of socioeconomic status. Secondhand smoke, exposure to chemicals such as pesticides and some household cleaning products, allergens such as dust mites, fire and burn hazards, and fall hazards such as clutter and poor lighting can be found in many homes and in all neighborhoods. These hazards can result in a multitude of health effects, including poisonings, fire and fall-related injuries, and lung diseases such as cancer and asthma (Matte and Jacobs 2000).

Some populations are disproportionately affected by health and housing issues. For people with disabilities, certain design elements and construction characteristics of homes, such as stairs or narrow doorways, can limit an entire range of housing options and adversely affect ease of access to and within the house. A home’s design features can either exclude or enhance the ability of a person with disabilities to participate in the community. Appropriate housing design and construction, on the other hand, can allow the elderly to remain at home and function independently rather than move to an assisted living facility or nursing home. Residents of homes with significant upkeep problems and structural and safety defects, such as lack of specific safety devices, deferred maintenance, moisture, and pest infestation, are also at increased risk for housing-related illness, injury, and disability. Moreover, some hazards are more common in certain geographic locations. For example, radon gas levels and the potential for extreme weather conditions and disasters vary across the country (Committee on Health Risks of Exposure to Radiation [BEIR VI] 1999; World Meteorological Organization undated).

A comprehensive, coordinated approach to healthy homes will result in the greatest public health impact. Directing resources toward a single disease or condition rather than working to improve the overall housing environment is inefficient and does not address residents’ health and safety risks holistically. Consequently, some practitioners and researchers have begun promoting a more comprehensive and coordinated approach to improving health and safety in homes (Jacobs et al. 2007; Sharfstein and Sandel 1998). Health care workers who visit homes also recognize that the residents they serve often face multiple health and safety issues. Because of economies of scale and more efficient use of human and other resources, a holistic approach can be less expensive than addressing problems individually (U.S. Department of Housing and Urban Development 2000). Finally, the holistic approach may enhance housing affordability both by reducing the costs associated with uncoordinated housing improvements and because one intervention may address two or more adverse health conditions. For example, repairs to deteriorated lead-based paint caused by a roof leak can be less expensive if the roof leak and the deteriorated paint repairs are coordinated; just repairing the paint without fixing the leak would be more expensive because deterioration would continue, leading to more repairs and increased costs over the long run. Repairing holes in floors may not only prevent falls but also reduce the possibility of pests entering the house.

In this Call to Action, the term homes includes not only the dwelling itself, but also the land immediately around the house and any other structures on the property. A healthy home is sited, designed, built, renovated, and maintained in ways that support the health of residents. Healthy houses can be single-family homes, apartments, townhomes, duplexes, condominiums, or manufactured homes.

Three pictures of different types of houses: a single-family suburban house; a row of stucco townhouses; and a high-rise, multifamily apartment building.

The concept of healthy homes extends beyond the four walls of a dwelling to its surroundings—to the land immediately around the house, to adjacent structures and amenities (such as outbuildings, trees, and recreational equipment), and to the neighborhood setting. A house does not exist in isolation. Although the larger community context of a house is generally beyond the scope of this document, it is part of a larger community; the place from which people depart to work, play, study, and interact with others; and the place to which they return from these activities. Community factors including the ways people behave and relate to each other, the way the community is designed and built, and the state of the environment, contribute critically to healthy homes. Health-promoting features of the community may include sidewalks and bicycle trails; parks and green space; mass transit; and nearby destinations such as stores, schools, and workplaces. Many of these features are encompassed in the approach known as “smart growth” (Frumkin et al. 2004). In addition, the ways people behave and relate to each other are also essential to health.

This Call to Action also emphasizes the public health importance of ensuring the availability of safe, healthy, affordable, accessible, and environmentally friendly homes for the U.S. population. Additionally, it describes housing-related health and safety issues for which interventions are available, as well as areas where further research and evaluation are needed. The costs and benefits of some interventions have been demonstrated; for these interventions the savings for both the medical and housing sectors can be substantial. The problems, consequences, and remedies for unhealthy housing are described in subsequent sections.