# Resources

## Federal Departments, Agencies, and Offices

- Administration on Aging
- U.S. Department of Health and Human Services
- http://www.aoa.gov

- Administration on Developmental Disabilities
- Administration for Children and Families
- U.S. Department of Health and Human Services
- http://www.acf.gov
- http://www.acf.dhhs.gov/programs/add/index.htm

- Center for Financing, Access and Cost Trends
- Agency for Healthcare Research and Quality
- U.S. Department of Health and Human Services
- http://www.ahrq.gov

- Centers for Medicare and Medicaid Services
- U.S. Department of Health and Human Services
- http://www.cms.hhs.gov

- Clearinghouse on Disability Information
- Office of Special Education and Rehabilitative Services
- U.S. Department of Education
- http://www.ed.gov

- Department of Defense
- http://www.defenselink.mil

- Department of Homeland Security
- http://www.dhs.gov

- Department of Housing and Urban Development
- http://www.hud.gov/groups/disabilities.cfm

- Department of Labor
- DisabilityInfo.gov
- http://www.disabilityinfo.gov

- Disability Rights Section
- Civil Rights Division
- U.S. Department of Justice
- http://www.usdoj.gov/crt/drs/drshome.htm

- Division of Human Development and Disability
- National Center on Birth Defects and Developmental
- Disabilities
- Centers for Disease Control and Prevention
- U.S. Department of Health and Human Resources
- http://www.cdc.gov

- Federal Transit Administration
- U.S. Department of Transportation
- http://www.ftadot.gov/

- Health Resources and Services Administration
- U.S. Department of Health and Human Services
- http://www.hrsa.gov

- Indian Health Service
- U.S. Department of Health and Human Services
- http://www.ihs.gov

- Interagency Committee on Disability Research (ICDR)
- http://icdr.us/

- National Center on Medical Rehabilitation Research
- National Institute of Child Health and Human
- Development
- National Institutes of Health
- U.S. Department of Health and Human Services
- http://www.nichd.nih.gov

- National Council on Disability
- http://www.ncd.gov

- National Institute on Deafness and Other
- Communication Disorders
- National Institutes of Health
- U.S. Department of Health and Human Services
- http://www.nih.gov/nidcd

- National Institute on Disability and Rehabilitation
- Research
- U.S. Department of Education
- http://www.ed.gov

- Office for Civil Rights
- U.S. Department of Health and Human Services
- http://www.hhs.gov/ocr/

- Office of Disability Employment Policy
- U.S. Department of Labor
- http://www.dol.gov/odep

- Office of Equal Opportunity and Diversity
- Management
- National Institutes of Health
- U.S. Department of Health and Human Services
- http://nih.hhs.gov

- Office of Public Health Emergency Preparedness
- U.S. Department of Health and Human Services
- http://www.hhs.gov/ophep/

- Office of Special Education and Rehabilitative Services
- U.S. Department of Education
- http://www.ed.gov

- Office of the President's Council on Physical Fitness and Sports
- U.S. Department of Health and Human Services
- http://www.fitness.gov

- Office on Disability
- U.S. Department of Health and Human Services
- http://www.hhs.gov/od/

- Office on Women's Health
- U.S. Department of Health and Human Services
- http://www.4woman.gov

- President’s Committee on Persons with Intellectual
- Disorders, Agency for Children and Families
- U.S. Department of Health and Human Services
- http://www.acf.hhs.gov/programs/pcpid/

- The President's Challenge Physical Activity and Fitness
- Awards Program
- http://www.presidentschallenge.org

- Social Security Administration
- http://www.ssa.gov

- Substance Abuse and Mental Health Services
- Administration
- U.S. Department of Health and Human Services
- http://www.samhsa.hhs.gov

## Private Resources

[This list is not all inclusive; inclusion neither represents nor otherwise suggests endorsement by the U.S. Department of Health and Human Services.]

- AARP (American Association of Retired Persons
- http://aarp.org

- ADAPT
- http://www.adapt.org

- Alliance Project (special education)
- http://www.alliance.org

- Alliance for Technology Access
- http://www.atacess.org

- American Academy of Pediatrics
- http://www.aap.org

- American Academy of Physical Medicine and Rehabilitation
- http://www.aaprm.org

- American Alliance for Health, Physical Education, Recreation, and Dance
- http://www.aahperd.org

- American Association for Geriatric Psychiatry
- http://www.aagpgpa.org

- American Association for Homecare
- http://aahomecare.org

- American Association of Mental Retardation
- http://www.aamr.org

- American Association of Occupational Therapy
- http://www.aota.org

- American Association of People with Disabilities
- http://www.aapd.com

- American Association on Health and Disability
- http://www.aahd.us

- American Council of the Blind
- http://www.acb.org

- American College of Sports Medicine
- http://www.acsm.org

- American Foundation for the Blind
- http://www.afb.org

- American Health Care Association
- http://www.ahca.org

- American Indian Rehabilitation Research and training Center
- http://www.nau.edu/ihd/airrtc

- American Physical Therapy Association
- http://www.apta.org

- American Society on Aging
- http://www.asaging.org

- American Speech-Language-Hearing Association
- http://www.asha.org

- American Therapeutic Recreation Association
- http://www.atra-tr.org

- ANCOR
- http://www.ancor.org

- Arc of the United States
- http://www.thearc.org

- Asian Community Mental Health Services
- http://www.igc.apc.org/acmhs

- Association of Maternal and Child Health Programs
- http://www.amchp.org

- Association of University Centers on Disability
- http://www.aucd.org

- Breast Health Access for Women with Disabilities
- http://www.bhawd.org

- Center for Medicare Advocacy
- http://www.medicareadvocacy.org

- Center for Research on Women with Disabilities
- http://www.bcm.edu

- Center for Universal Design
- http://www.design.ncsu.edu/cud

- Child Welfare League of America
- http://www.cwla.org

- Christopher and Dana Reeve Paralysis Resource Center
- http://www.paralysis.org

- Council for Exceptional Children
- http://www.cec.sped.org

- Disabled American Veterans
- http://www.dav.org

- Diabetes Research and Wellness Foundation
- http://www.diabeteswellness.net

- Disability Service Providers of America
- http://www.dspofamerica.org

- Disabled Sports USA
- http://www.dsusa.org

- Disabled Women’s Alliance
- http://www.disabilityhistory.org

- Easter Seals
- http://www.easterseals.com

- Educational Resources Information Center on Disabilities and Gifted Education
- http://www.ericec.org

- Epilepsy Foundation
- http://www.epilepsyfoundation.org

- Exceptional Parent
- http://www.eparent.com

- Family Voices
- www.familyvoices.org

- Federation of Families for Children’s Mental Health
- http://www.ffcmh.org

- Georgetown University Center for Child and Human Development
- http://gucchd.georgetown.edu

- Goodwill Industries International
- http://www.goodwill.org

- Howard University Research and Training Center for Access to Rehabilitation and Economic Opportunity
- http://www.law.howard.edu/hurtc/hurtc.html

- International Center for Bioethics, Culture and Disability
- http://www.bioethicsanddisability.org

- Kids Enjoy Exercise Now (K.E.E.N.)
- http://www.keenusa.org

- March of Dimes
- http://www.marchofdimes.com

- National Adult Day Services Association
- http://www.nadsa.org

- National Alliance for Accessible Golf
- http://www.accessgolf.org

- National Alliance for Hispanic Health Centers for Providers
- http://www.hispanichealth.org

- National Alliance for the Mentally Ill
- http://www.nami.org

- National Asian Pacific Center on Aging
- http://www.napca.org

- National Association of Alcohol, Drugs and Disability
- http://www.naadd.org

- National Association of Protection and Advocacy Systems
- http://www.napas.org

- National Association of State Alcohol and Drug Abuse
- Directors
- http://www.nasadad.org

- National Association of State Directors of Special Education
- http://www.nasdse.org

- National Association of State Medicaid Directors
- http://www.nasmd.org

- National Association of State Mental Health Program
- Directors
- http://www.nasmhpd.org

- National Association of State Units on Aging
- http://www.nasua.org

- National Catholic Partnership on Disability
- http://www.ncpd.org

- National Center for Disability Services
- http://www.business-disability.com

- National Center on Physical Activity and Disability
- http://www.ncpad.org

- National Clearinghouse on Managed Care and Long-term Support and Services for People with Developmental Disabilities and Their Families
- http://www.mcare.net

- National Council on the Aging
- http://www.ncoa.org

- National Information Center for Children and Youth with Disabilities
- http://www.nichcy.org

- National Industries for the Severely Handicapped
- http://www.nish.org

- National Limb Loss Information Center
- http://www.amputee-coalition.orgl

- National Mental Health Association
- http://www.nmha.org

- National Organization on Disability
- http://www.nod.org

- National Rehabilitation Association
- http://www.nationalrehab.org

- National Rehabilitation Information Center (NARIC)
- http://www.naric.com

- National Resource Center on AD/HD: A program of CHADD
- http://help4adhd.org

- National Spinal Cord Injury Association
- http://www.spinalcord.org

- Native American Training and Research Center
- http://www.ahsc.arizona.edu/nartc

- Paralyzed Veterans of America
- http://www.pva.org

- Parent Advocacy Coalition for Educational Rights (PACER)
- http://www.pacer.org

- Programs and Services Center of Minority Research in Special Education (COMRISE)
- http://www.curry.ed.school.virginia.edu/go/comrise

- Rehabilitation Engineering and Assistive Technology
- Society of North America
- http://www.resna.org

- Special Olympics
- http://www.specialolympics.org

- Spina Bifida Association of America (SBAA)
- www.sbaa.org

- United Cerebral Palsy Association
- http://www.ucp.org

- United Spinal Association
- http://www.unitedspinal.org

- Veterans of Foreign War
- http://www.vfwdc.org